# Effectiveness of Treatments for Menopausal Symptoms in Selected Subgroups

## Vasomotor Symptoms

Table N-1 Vasomotor outcomes by age subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Hedrick, 2010, Multinational | Mean change in daily MSHFNS | Age < 50 | Placebo | 24 | -6.4
Hedrick, 2010, Multinational | Mean change in daily MSHFNS | Age < 50 | 0.25 mg estradiol | 21 | -8.5
Hedrick, 2010, Multinational | Mean change in daily MSHFNS | Age < 50 | 0.50 mg estradiol | 29 | -6.7
Hedrick, 2010, Multinational | Mean change in daily MSHFNS | Age < 50 | 1.0 mg estradiol | 36 | -9.3
Hedrick, 2010, Multinational | Mean change in daily MSHFNS
Hedrick, 2010, Multinational | Mean change in daily MSHFNS | Age 50-59 | Placebo | 77 | -5.1
Hedrick, 2010, Multinational | Mean change in daily MSHFNS | Age 50-59 | 0.25 mg estradiol | 73 | -8.0^a^
Hedrick, 2010, Multinational | Mean change in daily MSHFNS | Age 50-59 | 0.50 mg estradiol | 68 | -7.9^a^
Hedrick, 2010, Multinational | Mean change in daily MSHFNS | Age 50-59 | 1.0 mg estradiol | 59 | -8.3^a^
Hedrick, 2010, Multinational | Mean change in daily MSHFNS
Hedrick, 2010, Multinational | Mean change in daily MSHFNS | Age ≥ 60 | Placebo | 23 | -4.7
Hedrick, 2010, Multinational | Mean change in daily MSHFNS | Age ≥ 60 | 0.25 mg estradiol | 27 | -6.7
Hedrick, 2010, Multinational | Mean change in daily MSHFNS | Age ≥ 60 | 0.50 mg estradiol | 22 | -7.1
Hedrick, 2010, Multinational | Mean change in daily MSHFNS | Age ≥ 60 | 1.0 mg estradiol | 29 | -9.7^a^
Hedrick, 2010, Multinational
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score | Age < 50 | Placebo | 24 | -0.8
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score | Age < 50 | 0.25 mg estradiol | 21 | -1.0
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score | Age < 50 | 0.50 mg estradiol | 29 | -0.9
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score | Age < 50 | 1.0 mg estradiol | 36 | -1.2
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score | Age 50-59 | Placebo | 77 | -0.4
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score | Age 50-59 | 0.25 mg estradiol | 73 | -0.7
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score | Age 50-59 | 0.50 mg estradiol | 68 | -1.0^b^
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score | Age 50-59 | 1.0 mg estradiol | 59 | -1.4^b^
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score | Age ≥ 60 | Placebo | 23 | -0.4
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score | Age ≥ 60 | 0.25 mg estradiol | 27 | -1.2^a^
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score | Age ≥ 60 | 0.50 mg estradiol | 22 | -1.1^c^
Hedrick, 2010, Multinational | Mean change in MSHFNS severity score | Age ≥ 60 | 1.0 mg estradiol | 29 | -1.6^b^
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo | Age <55 | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo | Age <55 | Chinese herbs | NR | -0.94 (95% CI: -1.7 to -0.14)
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo | Age ≥ 55 | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo | Age ≥ 55 | Chinese herbs | NR | 0.51 (95% CI: -0.56 to 1.60)
Rigano, 2001, Italy | Percent with hot flashes | Age 48-50 | Placebo | 75 | 86%
Rigano, 2001, Italy | Percent with hot flashes | Age 48-50 | 0.05 mg estradiol | 88 | 20%
Rigano, 2001, Italy | Percent with hot flashes
Rigano, 2001, Italy | Percent with hot flashes | Age 51-53 | Placebo | 61 | 39%
Rigano, 2001, Italy | Percent with hot flashes | Age 51-53 | 0.05 mg estradiol | 52 | 38%
Rigano, 2001, Italy | Percent with hot flashes
Rigano, 2001, Italy | Percent with hot flashes | Age 54-56 | Placebo | 55 | 83%
Rigano, 2001, Italy | Percent with hot flashes | Age 54-56 | 0.05 mg estradiol | 31 | 0%

MENQOL: Menopause-Specific Quality of Life; MSHFNS: moderate to severe hot flashes and night sweats; NR: not reported

a difference from placebo: p<0.01

b difference from placebo: p<0.001

c difference from placebo: p<0.05

Table N-2 Vasomotor outcomes by BMI subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Tice, 2003, United States | Percent reduction in THF | BMI < 25 | Placebo | NR | 40% (95% CI: 26 to 55%)
Tice, 2003, United States | Percent reduction in THF | BMI < 25 | 57.2 mg isoflavones | NR | 22% (95% CI: 7 to 37%)
Tice, 2003, United States | Percent reduction in THF | BMI < 25 | 82.0 mg isoflavones | NR | 30% (95% CI: 16 to 44%)
Tice, 2003, United States | Percent reduction in THF
Tice, 2003, United States | Percent reduction in THF | BMI ≥ 25 | Placebo | NR | 32% (95% CI: 21 to 42%)
Tice, 2003, United States | Percent reduction in THF | BMI ≥ 25 | 57.2 mg isoflavones | NR | 45% (95% CI: 32 to 59%)
Tice, 2003, United States | Percent reduction in THF | BMI ≥ 25 | 82.0 mg isoflavones | NR | 49% (95% CI: 35 to 63%)
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo | BMI ≤ 25 | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo | BMI ≤ 25 | Chinese herbs | NR | -0.85 (95% CI: -1.6 to -0.08)
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo | BMI > 25 | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo | BMI > 25 | Chinese herbs | NR | 0.42 (95% CI: -0.73 to 1.58)

MENQOL: Menopause-Specific Quality of Life; NR: not reported; THF: total hot flashes

Table N-3 Vasomotor outcomes by race subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Freeman, 2011, United States | Mean change in daily THFNS | White | 10-20 mg escitalopram | 53 | -2.2 (95% CI: -3.5 to -0.87)
Freeman, 2011, United States | Mean change in daily THFNS | African american | 10-20 mg escitalopram | 47 | -0.48 (95% CI: -3.0 to 2.0)
Freeman, 2011, United States | Mean change in daily THFNS | Other | 10-20 mg escitalopram | 4 | -2.3 (95% CI: -7.8 to -3.2)

THFNS: total hot flashes and night sweats

Table N-4 Vasomotor outcomes by severity of symptoms subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Aso, 2012, Japan | Mean daily THF | < 3 hot flashes/day | Placebo | 32 | Base: 1.6 (SD:0.57); 12-wk: 0.70
Aso, 2012, Japan | Mean daily THF | < 3 hot flashes/day | 10 mg equol | 32 | Base: 1.5 (SD: 0.57); 12-wk: 0.59
Aso, 2012, Japan | Mean daily THF
Aso, 2012, Japan | Mean daily THF | ≥ 3 hot flashes/day | Placebo | 34 | Base: 4.4 (SD: 2.3); 12-wk change: -1.2 (SD:2.9)
Aso, 2012, Japan | Mean daily THF | ≥ 3 hot flashes/day | 10 mg equol | 28 | Base: 4.9 (SD: 2.3); 12-wk change: -2.9 (SD: 2.0)^a^
Lee, 2010, Korea | Mean change in MSHF | > 20 Kupperman Index score | Placebo | 28 | -3.9 (SD: 3.0)
Lee, 2010, Korea | Mean change in MSHF | > 20 Kupperman Index score
Lee, 2010, Korea | Mean change in MSHF | > 20 Kupperman Index score | 350 mg isoflavone | 29 | -5.4 (SD: 3.1)^b^
Maki, 2007, United States | Mean change in Green vasomotor score | Asymptomatic (hot flash severity score < 1.2) | Placebo | 57 | -0.8
Maki, 2007, United States | Mean change in Green vasomotor score | Asymptomatic (hot flash severity score < 1.2) | 0.625 mg CEE + 2.5 mg MPA | 41 | -1.0
Maki, 2007, United States | Mean change in Green vasomotor score
Maki, 2007, United States | Mean change in Green vasomotor score | Symptomatic (hot flash score ≥ 1.2) | Placebo | 45 | -1.6
Maki, 2007, United States | Mean change in Green vasomotor score | Symptomatic (hot flash score ≥ 1.2) | 0.625 mg CEE + 2.5 mg MPA | 36 | -2.8^c^
Pitkin, 2007, Multinational | Mean weekly MSHF | < 30 hotflashes/week | 1 mg E2V + 2.5 mg MPA | NR | Base: 18.7; 12-wk: 1.1; last: 0.61^d^
Pitkin, 2007, Multinational | Mean weekly MSHF | < 30 hotflashes/week | 1 mg E2V + 5 mg MPA | NR | Base: 21.8; 12-wk: 2.5; last: 1.4^d^
Pitkin, 2007, Multinational | Mean weekly MSHF | < 30 hotflashes/week | 2 mg E2V + 5 mg MPA | NR | Base: 16.7; 12-wk: 0.99; last: 0.61^d^
Pitkin, 2007, Multinational | Mean weekly MSHF
Pitkin, 2007, Multinational | Mean weekly MSHF | ≥ 30 HF/wk | 1 mg E2V + 2.5 mg MPA | NR | Base: 53.7; 12-wk: 5.3; last: 2.6^e^
Pitkin, 2007, Multinational | Mean weekly MSHF | ≥ 30 HF/wk | 1 mg E2V + 5 mg MPA | NR | Base: 51.3; 12-wk: 4.5; last: 4.9^e^
Pitkin, 2007, Multinational | Mean weekly MSHF | ≥ 30 HF/wk | 2 mg E2V + 5 mg MPA | NR | Base: 55.6; 12-wk: 3.2; last: 2.3^e^
Limpaphayom, 2006, Multinational | Mean daily THF | ≥ 3 HF/day | 0.3 mg CEE + 1.5 mg MPA | 37 | Base: 5.0; 12-wk: 0.71^d^; last: 0.35^d^
Limpaphayom, 2006, Multinational | Mean daily THF | ≥ 3 HF/day
Limpaphayom, 2006, Multinational | Mean daily THF | ≥ 3 HF/day | 0.45 mg CEE + 1.5 mg MPA | 31 | Base: 5.4; 12-wk: 0.86^d,f^; last: 0.35^d,f^
Limpaphayom, 2006, Multinational | Mean daily THF | ≥ 3 HF/day
Limpaphayom, 2006, Multinational | Mean daily THF | ≥ 3 HF/day | 0.625 mg CEE + 2.5 mg MPA | 25 | Base: 4.8; 12-wk: 0.56^d,f^; last: 0.41^d,f^
Frei-Kleiner, 2005, Switzerland | Reduction in weekly THF | ≥ 20 KI score | Placebo | 18 | 25%
Frei-Kleiner, 2005, Switzerland | Reduction in weekly THF | ≥ 20 KI score
Frei-Kleiner, 2005, Switzerland | Reduction in weekly THF | ≥ 20 KI score | 42 mg black cohosh | 35 | 53%^g^
Verhoeven, 2005, Netherlands | Reduction in daily THF | ≥ 9 HF/day | Placebo | NR | 34%
Verhoeven, 2005, Netherlands | Reduction in daily THF | ≥ 9 HF/day
Verhoeven, 2005, Netherlands | Reduction in daily THF | ≥ 9 HF/day | isoflavone + black cohosh | NR | 51%^f^
Crisafulli, 2004, Italy | Reduction in daily THF | > 5 HF score | Placebo | NR | 12-wk: 12.6%; 1 yr: 18.4%
Crisafulli, 2004, Italy | Reduction in daily THF | > 5 HF score
Crisafulli, 2004, Italy | Reduction in daily THF | > 5 HF score | 54 mg isoflavone | NR | 12-wk: 85.2%; 1 yr: 95.1%^h^
Crisafulli, 2004, Italy | Reduction in daily THF | > 5 HF score
Crisafulli, 2004, Italy | Reduction in daily THF | > 5 HF score | 1 mg estradiol + 0.5 mg NETA | NR | 12-wk: 49.3%; 1 yr: 56.3%^h^
Burke, 2003, United States | Daily THFNS | ≥ 4 THFNS | Placebo | 34 | Base: 7.4 (SD: 3.3); last: 1.8 (SD: 2.9)^i^
Burke, 2003, United States | Daily THFNS | ≥ 4 THFNS
Burke, 2003, United States | Daily THFNS | ≥ 4 THFNS | 42 mg isoflavone | 27 | Base: 6.5 (SD: 2.9); last: 2.0 (SD: 3.2)^i, f^
Burke, 2003, United States | Daily THFNS | ≥ 4 THFNS
Burke, 2003, United States | Daily THFNS | ≥ 4 THFNS | 58 mg isoflavone | 28 | Base: 9.0 (SD:3.6); last: 2.7 (SD: 3.8)^i, f^

CEE: conjugated equine estrogen; E2V: estradiol valerate; MPA: medroxyprogesterone acetate; MSHF: moderate to severe hot flashes; NETA: norethisterone acetate; NR: not reported; THF: total hot flashes; THFNS: total hot flashes and night sweats

a difference from placebo: p<0.009

b difference from placebo: p<0.05

c difference from placebo: p=0.001

d pre/post: p<0.05

e pre/post: p<0.001

f no difference between subgroups

g difference from placebo: p=0.018

h difference from placebo: p<0.01

i pre/post: p<0.0001

Table N-5 Vasomotor outcomes by time since menopause subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Lobo, 2009, Multinational | Difference in MENQOL vasomotor score | < 5 yrs menopause | Placebo | 154 | -0.6 (SD: 1.2)
Lobo, 2009, Multinational | Difference in MENQOL vasomotor score | < 5 yrs menopause | 0.45 CEE + 20 mg bazedoxifene | 162 | -1.6 (SD: 1.3)^a^
Lobo, 2009, Multinational | Difference in MENQOL vasomotor score | < 5 yrs menopause | 0.625 mg CEE + 20 mg bazedoxifene | 161 | -1.8 (SD: 1.3)^a^
Lobo, 2009, Multinational | Difference in MENQOL vasomotor score
Lobo, 2009, Multinational | Difference in MENQOL vasomotor score | ≥ 5 yrs menopause | Placebo | 273 | -0.4 (SD: 1.7)
Lobo, 2009, Multinational | Difference in MENQOL vasomotor score | ≥ 5 yrs menopause | 0.45 CEE + 20 mg bazedoxifene | 271 | -1.0 (SD: 1.6)^a^
Lobo, 2009, Multinational | Difference in MENQOL vasomotor score | ≥ 5 yrs menopause | 0.625 mg CEE + 20 mg bazedoxifene | 253 | -1.2 (SD: 1.6)^a^
Utian, 2009, United States | Difference in MENQOL vasomotor score | < 5 yrs menopause | Placebo | 40 | -1.8 (SD: 1.9)
Utian, 2009, United States | Difference in MENQOL vasomotor score | < 5 yrs menopause | 0.45 CEE + 20 mg bazedoxifene | 82 | -3.4 (SD:1.8)^a^
Utian, 2009, United States | Difference in MENQOL vasomotor score | < 5 yrs menopause | 0.625 mg CEE + 20 mg bazedoxifene | 81 | -3.7 (SD: 2.7)^a^
Utian, 2009, United States | Difference in MENQOL vasomotor score
Utian, 2009, United States | Difference in MENQOL vasomotor score | ≥ 5 yrs menopause | Placebo | 23 | -1.6 (SD: 2.4)
Utian, 2009, United States | Difference in MENQOL vasomotor score | ≥ 5 yrs menopause | 0.45 CEE + 20 mg bazedoxifene | 45 | -3.7 (SD: 2.0)^a^
Utian, 2009, United States | Difference in MENQOL vasomotor score | ≥ 5 yrs menopause | 0.625 mg CEE + 20 mg bazedoxifene | 47 | -4.4 (SD: 2.7)^a^
Osmers, 2005, Germany | Difference in MRS vasomotor score from placebo | Early climacteric | Placebo | NR | -
Osmers, 2005, Germany | Difference in MRS vasomotor score from placebo | Early climacteric | 40 mg black cohosh | NR | -0.11 (95% CI: -0.17 to -0.04)^b^
Osmers, 2005, Germany | Difference in MRS vasomotor score from placebo
Osmers, 2005, Germany | Difference in MRS vasomotor score from placebo | Late climacteric | Placebo | NR | -
Osmers, 2005, Germany | Difference in MRS vasomotor score from placebo | Late climacteric | 40 mg black cohosh | NR | -0.07 (95% CI: -0.13 to -0.02)^c^
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo | < 4 yrs amenorrhea | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo | < 4 yrs amenorrhea | Chinese herbs | NR | -0.31 (95% CI: -1.7 to 1.1)
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo | ≥ 4 yrs amenorrhea | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL vasomotor score from placebo | ≥ 4 yrs amenorrhea | Chinese herbs | NR | -0.09 (95% CI: -0.61 to 0.42)
Davis, 2001, Australia
Davis, 2001, Australia | Difference in reduction of THFNS from placebo | < 4 yrs amenorrhea | Placebo | NR | -
Davis, 2001, Australia | Difference in reduction of THFNS from placebo | < 4 yrs amenorrhea | Chinese herbs | NR | 4.8% (95% CI: -24.6 to 34.2%)
Davis, 2001, Australia | Difference in reduction of THFNS from placebo
Davis, 2001, Australia | Difference in reduction of THFNS from placebo | > 4 yrs amenorrhea | Placebo | NR | -
Davis, 2001, Australia | Difference in reduction of THFNS from placebo | > 4 yrs amenorrhea | Chinese herbs | NR | 26.8% (95% CI: 3.8 to 49.9%)
Simon, 2001, United States | Reduction in daily MSHF | 0 to ≤ 6 mos last menses | Placebo | 15 | -74.0% (SD: 31.0)
Simon, 2001, United States | Reduction in daily MSHF | 0 to ≤ 6 mos last menses | 0.625 mg CEE | 18 | -77.5 (SD: 27.6)^d^
Simon, 2001, United States | Reduction in daily MSHF
Simon, 2001, United States | Reduction in daily MSHF | 6 to ≤ 12 mos last menses | Placebo | 1 | -27.9% (SD: 0.0)
Simon, 2001, United States | Reduction in daily MSHF | 6 to ≤ 12 mos last menses | 0.625 mg CEE | 6 | -82.6 (SD: 32.1)^d^
Simon, 2001, United States | Reduction in daily MSHF
Simon, 2001, United States | Reduction in daily MSHF | 12 to ≤ 36 mos last menses | Placebo | 6 | -46.7 (SD: 40.9)
Simon, 2001, United States | Reduction in daily MSHF | 12 to ≤ 36 mos last menses | 0.625 mg CEE | 13 | -85.2 (SD: 29.6)^e^
Simon, 2001, United States | Reduction in daily MSHF
Simon, 2001, United States | Reduction in daily MSHF | > 36 mos last menses | Placebo | 25 | -53.1 (SD: 44.0)
Simon, 2001, United States | Reduction in daily MSHF | > 36 mos last menses | 0.625 mg CEE | 33 | -80.1 (SD: 32.7)^e^
Baerug, 1998, Norway | Weekly HFS | Late perimenopausal | Placebo | NR | Baseline: 100.2; 12-wk: 38.0
Baerug, 1998, Norway | Weekly HFS | Late perimenopausal | 1 mg estradiol + 0.25 mg NETA | NR | Baseline: 107.1; 12-wk: 1.4
Baerug, 1998, Norway | Weekly HFS | Late perimenopausal | 1 mg estradiol + 0.5 mg NETA | NR | Baseline: 105.3; 12-wk: 1.2
Baerug, 1998, Norway | Weekly HFS
Baerug, 1998, Norway | Weekly HFS | Postmenopausal | Placebo | NR | Baseline: 124.5; 12-wk: 79.3
Baerug, 1998, Norway | Weekly HFS | Postmenopausal | 1 mg estradiol + 0.25 mg NETA | NR | Baseline: 126.9; 12-wk: 10.8
Baerug, 1998, Norway | Weekly HFS | Postmenopausal | 1 mg estradiol + 0.5 mg NETA | NR | Baseline: 127.5; 12-wk: 7.4

CEE: conjugated equine estrogen; HFS: hot flash score; MENQOL: Menopause Quality of Life scale; MRS: Menopause Rating Scale; MSHF: moderate to severe hot flashes; NR: not reported; SD: standard deviation

a difference from placebo: p≤0.001

b difference from placebo: p=0.002

c difference from placebo: p=0.006

d difference from placebo: NS

e difference from placebo: p<0.05

Table N-6 Vasomotor outcomes by uterus status subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Hedrick, 2010 Multinational | Mean change in daily MSHFNS | Absent uterus | Placebo | 71 | -5.9
Hedrick, 2010 Multinational | Mean change in daily MSHFNS | Absent uterus | 0.25 mg estradiol | 58 | -8.8^a^
Hedrick, 2010 Multinational | Mean change in daily MSHFNS | Absent uterus | 0.50 mg estradiol | 62 | -7.0
Hedrick, 2010 Multinational | Mean change in daily MSHFNS | Absent uterus | 1.0 mg estradiol | 68 | -9.7^b^
Hedrick, 2010 Multinational | Mean change in daily MSHFNS
Hedrick, 2010 Multinational | Mean change in daily MSHFNS | Intact uterus | Placebo | 53 | -4.4
Hedrick, 2010 Multinational | Mean change in daily MSHFNS | Intact uterus | 0.25 mg estradiol | 63 | -7.0
Hedrick, 2010 Multinational | Mean change in daily MSHFNS | Intact uterus | 0.50 mg estradiol | 57 | -8.0^c^
Hedrick, 2010 Multinational | Mean change in daily MSHFNS | Intact uterus | 1.0 mg estradiol | 56 | -8.0^c^
Hedrick, 2010 Multinational
Hedrick, 2010 Multinational | Mean change in daily MSHFNS severity score | Absent uterus | Placebo | 71 | -0.5
Hedrick, 2010 Multinational | Mean change in daily MSHFNS severity score | Absent uterus | 0.25 mg estradiol | 58 | -0.8
Hedrick, 2010 Multinational | Mean change in daily MSHFNS severity score | Absent uterus | 0.50 mg estradiol | 62 | -0.8
Hedrick, 2010 Multinational | Mean change in daily MSHFNS severity score | Absent uterus | 1.0 mg estradiol | 68 | -1.4^c^
Hedrick, 2010 Multinational | Mean change in daily MSHFNS severity score
Hedrick, 2010 Multinational | Mean change in daily MSHFNS severity score | Intact uterus | Placebo | 53 | -0.4
Hedrick, 2010 Multinational | Mean change in daily MSHFNS severity score | Intact uterus | 0.25 mg estradiol | 63 | -0.9^a^
Hedrick, 2010 Multinational | Mean change in daily MSHFNS severity score | Intact uterus | 0.50 mg estradiol | 57 | -1.2^c^
Hedrick, 2010 Multinational | Mean change in daily MSHFNS severity score | Intact uterus | 1.0 mg estradiol | 56 | -1.4^c^

MSHFNS: moderate-to-severe hot flashes and night sweats; N: number

a difference from placebo: p<0.05

b difference from placebo: p<0.001

c difference from placebo: p<0.01

## Sexual Function

Table N-7 Sexual function outcomes by age subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Brunner, 2005, United States | Mean change in satisfaction score^a^ | Age 50-54 with MSVS | Placebo | 134 | 0.02 (SD: 1.2)
Brunner, 2005, United States | Mean change in satisfaction score^a^ | Age 50-54 with MSVS
Brunner, 2005, United States | Mean change in satisfaction score^a^ | Age 50-54 with MSVS | 0.625 mg CEE | 140 | -0.07 (SD: 1.1)^b^
Hays, 2003, United States | Mean change in satisfaction score^a^ | Age 50-54 with MSVS | Placebo | 201 | -0.2 (SD: 1.3)
Hays, 2003, United States | Mean change in satisfaction score^a^ | Age 50-54 with MSVS
Hays, 2003, United States | Mean change in satisfaction score^a^ | Age 50-54 with MSVS | 0.625 mg CEE + 2.5 mg MPA | 221 | 0.1 (SD: 1.2)^c^
Davis, 2001, Australia | Difference in MENQOL sex score from placebo | Age < 55 | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL sex score from placebo | Age < 55 | Chinese herbs | NR | -0.72 (95% CI: -2.8 to 1.4)
Davis, 2001, Australia | Difference in MENQOL sex score from placebo
Davis, 2001, Australia | Difference in MENQOL sex score from placebo | Age ≥ 55 | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL sex score from placebo | Age ≥ 55 | Chinese herbs | NR | -0.14 (95% CI: -1.3 to 1.0)
Rigano, 2001, Italy | Percent reporting decrease in sexual activity | Age 48-50 | Placebo | 75 | 44%
Rigano, 2001, Italy | Percent reporting decrease in sexual activity | Age 48-50 | 0.05 mg estradiol | 88 | 48%
Rigano, 2001, Italy | Percent reporting decrease in sexual activity
Rigano, 2001, Italy | Percent reporting decrease in sexual activity | Age 51-53 | Placebo | 61 | 62%
Rigano, 2001, Italy | Percent reporting decrease in sexual activity | Age 51-53 | 0.05 mg estradiol | 52 | 75%
Rigano, 2001, Italy | Percent reporting decrease in sexual activity
Rigano, 2001, Italy | Percent reporting decrease in sexual activity | Age 54-56 | Placebo | 55 | 48%
Rigano, 2001, Italy | Percent reporting decrease in sexual activity | Age 54-56 | 0.05 mg estradiol | 31 | 84%

CEE: conjugated equine estrogen; MENQOL: Menopause-specific Quality of Life; MPA: medroxyprogesterone acetate; MSV: moderate to severe vasomotor symptoms; NR: not reported

a Satisfaction score from a single question: 1=’very unsatisfied’ to 4=’very satisfied’

b difference between groups: p=0.50

c difference between groups: p=0.06

Table N-8 Sexual function outcomes by BMI subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Davis, 2001, Australia | Difference in MENQOL sex score from placebo | BMI ≤ 25 | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL sex score from placebo | BMI ≤ 25 | Chinese herbs | NR | -1.0 95% CI: -2.7 to 0.65)
Davis, 2001, Australia | Difference in MENQOL sex score from placebo
Davis, 2001, Australia | Difference in MENQOL sex score from placebo | BMI >25 | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL sex score from placebo | BMI >25 | Chinese herbs | NR | 0.18 (95% CI: -1.5 to 1.8)

MENQOL: Menopause-specific Quality of Life; NR: not reported

Table N-9 Sexual function outcomes by time since menopause subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Lobo, 2009, Multinational | Difference in MENQOL sexual score | < 5 yrs menopause | Placebo | 154 | -0.9 (SD: 1.2)
Lobo, 2009, Multinational | Difference in MENQOL sexual score | < 5 yrs menopause | 0.45 CEE + 20 mg bazedoxifene | 162 | -0.7 (SD: 1.3)
Lobo, 2009, Multinational | Difference in MENQOL sexual score | < 5 yrs menopause | 0.625 mg CEE + 20 mg bazedoxifene | 161 | -0.7 (SD: 1.3)
Lobo, 2009, Multinational | Difference in MENQOL sexual score
Lobo, 2009, Multinational | Difference in MENQOL sexual score | ≥ 5 yrs menopause | Placebo | 273 | -0.4 (SD: 1.7)
Lobo, 2009, Multinational | Difference in MENQOL sexual score | ≥ 5 yrs menopause | 0.45 CEE + 20 mg bazedoxifene | 271 | -0.6 (SD: 1.6)^a^
Lobo, 2009, Multinational | Difference in MENQOL sexual score | ≥ 5 yrs menopause | 0.625 mg CEE + 20 mg bazedoxifene | 253 | -0.7 (SD: 1.6)^b^
Utian, 2009, United States | Difference in MENQOL sexual score | < 5 yrs menopause | Placebo | 40 | -1.1 (SD: 1.9)
Utian, 2009, United States | Difference in MENQOL sexual score | < 5 yrs menopause | 0.45 CEE + 20 mg bazedoxifene | 82 | -1.4 (SD: 1.8)
Utian, 2009, United States | Difference in MENQOL sexual score | < 5 yrs menopause | 0.625 mg CEE + 20 mg bazedoxifene | 81 | -1.4 (SD: 1.8)
Utian, 2009, United States | Difference in MENQOL sexual score
Utian, 2009, United States | Difference in MENQOL sexual score | ≥ 5 yrs menopause | Placebo | 23 | -0.3 (SD: 1.9)
Utian, 2009, United States | Difference in MENQOL sexual score | ≥ 5 yrs menopause | 0.45 CEE + 20 mg bazedoxifene | 45 | -1.1 (SD: 2.0)
Utian, 2009, United States | Difference in MENQOL sexual score | ≥ 5 yrs menopause | 0.625 mg CEE + 20 mg bazedoxifene | 47 | -1.5 (SD: 2.1)^b^
Davis, 2001, Australia | Difference in MENQOL sex score from placebo | < 4 yrs amenorrhea | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL sex score from placebo | < 4 yrs amenorrhea | Chinese herbs | NR | 0.52 (95% CI: -1.6 to 2.6)
Davis, 2001, Australia | Difference in MENQOL sex score from placebo
Davis, 2001, Australia | Difference in MENQOL sex score from placebo | ≥ 4 yrs amenorrhea | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL sex score from placebo | ≥ 4 yrs amenorrhea | Chinese herbs | NR | -0.96 (95% CI: -2.1 to 0.16)

MENQOL: Menopause-specific Quality of Life; NR: not reported

a difference from placebo: p≤0.05

b difference from placebo: p<0.01

Table N-10 Sexual function outcomes by uterus status subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Davis, 2008, Multinational | Mean number satisfying sexual episodes per four weeks | Natural menopause | Placebo | 196 | Base: 2.4 (SD: 2.8); last: 3.0 (SD: 4.2)
Davis, 2008, Multinational | Mean number satisfying sexual episodes per four weeks | Natural menopause | 0.15 mg testosterone | 187 | Base: 2.8 (SD: 2.7); last: 4.0 (SD: 4.1)^a^
Davis, 2008, Multinational | Mean number satisfying sexual episodes per four weeks | Natural menopause | 0.30 mg testosterone | 189 | Base: 2.6 (SD: 2.8); last: 4.5 (SD: 5.5)^b^
Davis, 2008, Multinational | Mean number satisfying sexual episodes per four weeks
Davis, 2008, Multinational | Mean number satisfying sexual episodes per four weeks | Surgical menopause | Placebo | 69 | Base: 2.6 (SD: 2.5); last: 4.1 (SD: 4.2)
Davis, 2008, Multinational | Mean number satisfying sexual episodes per four weeks | Surgical menopause | 0.15 mg testosterone | 65 | Base: 3.1 (SD: 4.0); last 4.0 (SD: 4.8)
Davis, 2008, Multinational | Mean number satisfying sexual episodes per four weeks | Surgical menopause | 0.30 mg testosterone | 65 | Base: 2.0 (SD: 2.4); last: 4.4 (SD:5.6)

a difference from placebo: p=0.02

b difference from placebo: p<0.001

## Psychological Symptoms

Table N-11 Psychological outcomes by age subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Brunner, 2005, United States | Mean change in psychological score^a^ | Age 50-54 with MSVS | Placebo | 151 | 0.08 (SD: 2.59)
Brunner, 2005, United States | Mean change in psychological score^a^ | Age 50-54 with MSVS
Brunner, 2005, United States | Mean change in psychological score^a^ | Age 50-54 with MSVS | 0.625 mg CEE | 159 | -0.15 (SD: 2.63)^b^
Hays, 2003, United States | Mean change in psychological score^a^ | Age 50-54 with MSVS | Placebo | 213 | -0.4 (SD: 2.3)
Hays, 2003, United States | Mean change in psychological score^a^ | Age 50-54 with MSVS
Hays, 2003, United States | Mean change in psychological score^a^ | Age 50-54 with MSVS | 0.625 mg CEE + 2.5 mg MPA | 255 | -0.1 (SD: 2.4)^c^
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo | Age < 55 | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo | Age < 55 | Chinese herbs | NR | -0.22 (95% CI: -1.0 to 0.57)
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo | Age ≥ 55 | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo | Age ≥ 55 | Chinese herbs | NR | 0.10 (95% CI: -0.77 to 0.96)

CEE: conjugated equine estrogen; MPA: medroxyprogesterone acetate; MSVS: moderate to severe vasomotor symptoms; NR: not reported

a Center for Epidemiological Studies Depression Scale (6 items) plus Diagnostic Interview Schedule (2 items): range -8.2 (best) to 4.0 (worst)

b difference from placebo: p=0.44

c difference from placebo: p=0.23

Table N-12 Psychological outcomes by BMI subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo | BMI ≤ 25 | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo | BMI ≤ 25 | Chinese herbs | NR | -0.17 (95% CI: -1.01 to 0.68)
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo | BMI > 25 | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo | BMI > 25 | Chinese herbs | NR | 0.13 (95% CI: -0.68 to 0.95)

MENQOL: Menopause-specific Quality of Life; NR: not reported

Table N-13 Psychological outcomes by time since menopause subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Kornstein, 2010, United States | Mean change in Hamilton Depression Scale | Perimenopausal | Placebo | 37 | -6.8 (SD: 4.5)
Kornstein, 2010, United States | Mean change in Hamilton Depression Scale | Perimenopausal | 10 mg desvenlafaxine | 84 | -10.9 (SD: 4.9)^a^
Kornstein, 2010, United States | Mean change in Hamilton Depression Scale
Kornstein, 2010, United States | Mean change in Hamilton Depression Scale | Postmenopausal | Placebo | 88 | -7.8 (SD: 7.0)
Kornstein, 2010, United States | Mean change in Hamilton Depression Scale | Postmenopausal | 10 mg desvenlafaxine | 163 | -11.1 (SD: 6.8)^b^
Lobo, 2009, Multinational | Difference in MENQOL psychological score | < 5 yrs menopause | Placebo | 154 | -0.4 (SD: 1.2)
Lobo, 2009, Multinational | Difference in MENQOL psychological score | < 5 yrs menopause | 0.45 CEE + 20 mg bazedoxifene | 162 | -0.6 (SD: 1.3)
Lobo, 2009, Multinational | Difference in MENQOL psychological score | < 5 yrs menopause | 0.625 mg CEE + 20 mg bazedoxifene | 161 | -0.6 (SD: 1.3)
Lobo, 2009, Multinational | Difference in MENQOL psychological score
Lobo, 2009, Multinational | Difference in MENQOL psychological score | ≥ 5 yrs menopause | Placebo | 273 | -0.4 (SD: 1.7)
Lobo, 2009, Multinational | Difference in MENQOL psychological score | ≥ 5 yrs menopause | 0.45 CEE + 20 mg bazedoxifene | 271 | -0.4 (SD: 1.6)
Lobo, 2009, Multinational | Difference in MENQOL psychological score | ≥ 5 yrs menopause | 0.625 mg CEE + 20 mg bazedoxifene | 253 | -0.5 (SD: 1.6)
Utian, 2009, United States | Difference in MENQOL psychological score | < 5 yrs menopause | Placebo | 40 | -0.9 (SD: 1.3)
Utian, 2009, United States | Difference in MENQOL psychological score | < 5 yrs menopause | 0.45 CEE + 20 mg bazedoxifene | 82 | -1.0 (SD: 1.8)
Utian, 2009, United States | Difference in MENQOL psychological score | < 5 yrs menopause | 0.625 mg CEE + 20 mg bazedoxifene | 81 | -1.4 (SD: 1.8)
Utian, 2009, United States | Difference in MENQOL psychological score
Utian, 2009, United States | Difference in MENQOL psychological score | ≥ 5 yrs menopause | Placebo | 23 | -0.4 (SD: 1.9)
Utian, 2009, United States | Difference in MENQOL psychological score | ≥ 5 yrs menopause | 0.45 CEE + 20 mg bazedoxifene | 45 | -0.8 (SD: 2.0)
Utian, 2009, United States | Difference in MENQOL psychological score | ≥ 5 yrs menopause | 0.625 mg CEE + 20 mg bazedoxifene | 47 | -0.9 (SD: 2.1)
Osmers, 2005, Germany | Difference in MRS psychological score from placebo | Early climacteric | Placebo | NR | -
Osmers, 2005, Germany | Difference in MRS psychological score from placebo | Early climacteric | 40 mg black cohosh | NR | -0.04 (95% CI: -0.09 to 0.00)^c^
Osmers, 2005, Germany | Difference in MRS psychological score from placebo
Osmers, 2005, Germany | Difference in MRS psychological score from placebo | Late climacteric | Placebo | NR | -
Osmers, 2005, Germany | Difference in MRS psychological score from placebo | Late climacteric | 40 mg black cohosh | NR | -0.03 (95% CI: -0.06 to 0.00)^d^
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo | < 4 yrs amenorrhea | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo | < 4 yrs amenorrhea | Chinese herbs | NR | 0.18 (95% CI: -0.81 to 1.2)
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo | ≥ 4 yrs amenorrhea | Placebo | NR | -
Davis, 2001, Australia | Difference in MENQOL psychological score from placebo | ≥ 4 yrs amenorrhea | Chinese herbs | NR | -0.08 (95% CI: -0.70 to 0.54)
Strickler, 2000, United States | Mean change in WHQ anxiety score | < 4 yrs post menopause | Placebo | NR | -0.02
Strickler, 2000, United States | Mean change in WHQ anxiety score | < 4 yrs post menopause | 0.625 mg CEE | NR | -0.01^e^
Strickler, 2000, United States | Mean change in WHQ anxiety score
Strickler, 2000, United States | Mean change in WHQ anxiety score | ≥ 4 yrs post menopause | Placebo | NR | 0.06
Strickler, 2000, United States | Mean change in WHQ anxiety score | ≥ 4 yrs post menopause | 0.625 mg CEE | NR | -0.02^f^

CEE: conjugated equine estrogens; MENQOL: Menopause-specific Quality of Life; MRS: Menopause Rating Scale; NR: not reported; WHQ: Womens Health Questionnaire

a difference from placebo: -4.1 (95% CI: -6.8 to -1.4); p=0.003

b difference from placebo: -3.3 (95% CI: -5.1 to -1.5); p<0.001

c difference from placebo: p=0.048

d difference from placebo p=0.08

e difference from placebo: p=0.11

f difference from place bo: p=0.24

Table N-14 Psychological outcomes by comorbidity subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Strickler, 2000, United States | Mean change in WHQ anxiety score | < 3.5 baseline anxiety score | Placebo | NR | 0.19
Strickler, 2000, United States | Mean change in WHQ anxiety score | < 3.5 baseline anxiety score | 0.625 mg CEE | NR | 0.21^a^
Strickler, 2000, United States | Mean change in WHQ anxiety score
Strickler, 2000, United States | Mean change in WHQ anxiety score | ≥ 3.5 baseline anxiety score | Placebo | NR | -0.05
Strickler, 2000, United States | Mean change in WHQ anxiety score | ≥ 3.5 baseline anxiety score | 0.625 mg CEE | NR | -0.15^b^

CEE: conjugated equine estrogens; NR: not reported; PMS: premenstrual syndrome; PND: postnatal depression; WHQ: Womens Health Questionnaire

a difference from placebo: p=0.67

b difference from placebo: p=0.02

## Quality of Life

Table N-15 Quality of life outcomes for severity of symptom subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Lee, 2010, Korea | Mean change in KI total score | > 20 KI score | Placebo | 28 | -11.2 (SD: 6.8)
Lee, 2010, Korea | Mean change in KI total score | > 20 KI score
Lee, 2010, Korea | Mean change in KI total score | > 20 KI score | 350 mg isoflavone | 29 | -16.4 (SD: 8.8)^a^
Maki, 2007, United States | Mean change in Green total score | Asymptomatic | Placebo | 45 | -3.3
Maki, 2007, United States | Mean change in Green total score | Asymptomatic | 0.625 mg CEE + 2.5 mg MPA | 36 | -1.6
Maki, 2007, United States | Mean change in Green total score
Maki, 2007, United States | Mean change in Green total score | Symptomatic | Placebo | 38 | -3.6
Maki, 2007, United States | Mean change in Green total score | Symptomatic | 0.625 mg CEE + 2.5 mg MPA | 41 | -6.4^b^
Maki, 2007, United States
Maki, 2007, United States | Mean change in Utian QOL score | Asymptomatic | Placebo | 45 | 3.5
Maki, 2007, United States | Mean change in Utian QOL score | Asymptomatic | 0.625 mg CEE + 2.5 mg MPA | 36 | -1.3
Maki, 2007, United States | Mean change in Utian QOL score
Maki, 2007, United States | Mean change in Utian QOL score | Symptomatic | Placebo | 38 | -0.65
Maki, 2007, United States | Mean change in Utian QOL score | Symptomatic | 0.625 mg CEE + 2.5 mg MPA | 41 | 5.7^c^
Frei-Kleiner, 2005, Switzerland | Median KI total score | > 20 KI score | Placebo | 18 | Base: 24.0 (95% CI: 21.0 to 28.1); 12 wk: 17.0 (95% CI: 15 to 21.0)
Frei-Kleiner, 2005, Switzerland | Median KI total score | > 20 KI score
Frei-Kleiner, 2005, Switzerland | Median KI total score | > 20 KI score | 42 mg black cohosh | 35 | Base: 27.0 (95% CI: 24.0 to 28.0); 12 wk: 14.0 (95% CI: 10 to 18.0)^d^
Lopes, 2001, France | Mean KI total score | > 7 hot flashes/day | 0.05 mg estradiol patch | 83 | Base: 32.5 (SD: 5.6); 12-wk: 11.5 (SD:9.2)^e^
Lopes, 2001, France | Mean KI total score | > 7 hot flashes/day
Lopes, 2001, France | Mean KI total score | > 7 hot flashes/day | 0.3 mg estradiol spray | 68 | Base: 31.7 (SD:6.1); 12-wk: 12.3 (SD:9.1)^e, f^
Mattsson, 2000 | Mean KI total score | > 7 hot flashes/day | 2 mg estradiol + dydrogesterone oral | 110 | Base: 29.7 (SD: 4.8); 12-wk: 9.6 (SD: 8.9)
Mattsson, 2000 | Mean KI total score | > 7 hot flashes/day
Mattsson, 2000 | Mean KI total score | > 7 hot flashes/day | 0.3 mg estradiol + dydrogesterone spray | 102 | Base: 29.9 (SD: 6.1); 12-wk: 10.7 (SD: 9.4)^f^

CEE: conjugated equine estrogen; KI: Kupperman Index; QOL: quality of life

a difference between treatment groups: p<0.01

b difference from placebo: p=0.10

c difference from placebo: p=0.01

d difference from placebo group: p=0.018

e pre/post: p<0.05

f difference between treatment groups: p=NS

Table N-16 Quality of life outcomes for time since menopause subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Lobo, 2009, Multinational | Difference in MENQOL total score | < 5 yrs since menopause | Placebo | 154 | -0.6 (SD: 1.2)
Lobo, 2009, Multinational | Difference in MENQOL total score | < 5 yrs since menopause | 0.45 mg CEE + 20 mg bazedoxifene | 162 | -0.9 (SD: 1.3)^a^
Lobo, 2009, Multinational | Difference in MENQOL total score | < 5 yrs since menopause | 0.625 mg CEE + 20 mg bazedoxifene | 161 | -0.9 (SD: 1.3)^a^
Lobo, 2009, Multinational | Difference in MENQOL total score
Lobo, 2009, Multinational | Difference in MENQOL total score | ≥ 5 yrs since menopause | Placebo | 273 | -0.4 (SD: 1.7)
Lobo, 2009, Multinational | Difference in MENQOL total score | ≥ 5 yrs since menopause | 0.45 mg CEE + 20 mg bazedoxifene | 271 | -0.6 (SD: 1.6)^b^
Lobo, 2009, Multinational | Difference in MENQOL total score | ≥ 5 yrs since menopause | 0.625 mg CEE + 20 mg bazedoxifene | 253 | -0.7 (SD: 1.6)^b^
Utian, 2009, United States | Difference in MENQOL total score | < 5 yrs since menopause | Placebo | 40 | -1.2 (SD: 1.3)
Utian, 2009, United States | Difference in MENQOL total score | < 5 yrs since menopause | 0.45 mg CEE + 20 mg bazedoxifene | 82 | -1.8 (SD: 1.8)^c^
Utian, 2009, United States | Difference in MENQOL total score | < 5 yrs since menopause | 0.625 mg CEE + 20 mg bazedoxifene | 81 | -2.0 (SD: 1.8)^a^
Utian, 2009, United States | Difference in MENQOL total score
Utian, 2009, United States | Difference in MENQOL total score | ≥ 5 yrs since menopause | Placebo | 23 | -0.9 (SD: 1.4)
Utian, 2009, United States | Difference in MENQOL total score | ≥ 5 yrs since menopause | 0.45 mg CEE + 20 mg bazedoxifene | 45 | -1.6 (SD: 1.3)^c^
Utian, 2009, United States | Difference in MENQOL total score | ≥ 5 yrs since menopause | 0.625 mg CEE + 20 mg bazedoxifene | 47 | -2.1 (SD: 1.4)^b^
Osmers, 2005, Germany | Difference in MRS total score from placebo | Early climacteric | Placebo | NR | -
Osmers, 2005, Germany | Difference in MRS total score from placebo | Early climacteric | 40 mg black cohosh | NR | -0.06 (95% CI: -0.10 to -0.03)^d^
Osmers, 2005, Germany | Difference in MRS total score from placebo
Osmers, 2005, Germany | Difference in MRS total score from placebo | Late climacteric | Placebo | NR | -
Osmers, 2005, Germany | Difference in MRS total score from placebo | Late climacteric | 40 mg black cohosh | NR | -0.04 (95% CI: -0.07 to -0.02)^e^
Loh, 2002, Singapore | Change in mean KI total score | < 3 yrs menopausal | 1 mg estradiol + 0.5 mg NETA | NR | Baseline: 12.5 (SD: 7.4); change: -5.4 (SD: 7.1)
Loh, 2002, Singapore | Change in mean KI total score | < 3 yrs menopausal | 2 mg estradiol + 1 mg NETA | NR | Baseline: 15.2 (SD: 12.3); change: -6.8 (SD: 8.2)^f^
Loh, 2002, Singapore | Change in mean KI total score
Loh, 2002, Singapore | Change in mean KI total score | ≥ 3 yrs menopausal | 1 mg estradiol + 0.5 mg NETA | NR | Baseline: 13.3 (SD: 10.7); change: -5.0 (SD: 7.1)
Loh, 2002, Singapore | Change in mean KI total score | ≥ 3 yrs menopausal | 2 mg estradiol + 1 mg NETA | NR | Baseline: 13.2 (SD: 8.7); change: -3.3 (SD: 8.1)^g^

MRS: Menopausal Rating Scale; NETA: norethisterone acetate; NR: not reported

a difference from placebo: p<0.01

b difference from placebo: p≤0.001

c difference from placebo: p≤0.05

d difference from placebo: p<0.001

e difference from placebo: p=0.002

f difference between treatment groups: p=0.47

g difference between treatment groups: p=0.40

## Sleep Disturbance

Table N-17 Sleep disturbance outcomes by age subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Brunner, 2005, United States | Mean change in WHI sleep score | Age 50-54 with MSVS | Placebo | 157 | 0.53 (SD: 4.6)
Brunner, 2005, United States | Mean change in WHI sleep score | Age 50-54 with MSVS
Brunner, 2005, United States | Mean change in WHI sleep score | Age 50-54 with MSVS | 0.625 mg CEE | 165 | 1.4 (SD: 4.6)^a^
Hays, 2003, United States | Mean change in WHI sleep score | Age 50-54 with MSVS | Placebo | 216 | 0.8 (SD: 4.6)
Hays, 2003, United States | Mean change in WHI sleep score | Age 50-54 with MSVS
Hays, 2003, United States | Mean change in WHI sleep score | Age 50-54 with MSVS | 0.625 mg CEE + 2.5 mg MPA | 255 | 1.8 (SD: 4.8)^b^
Rigano, 2001, Italy | Percent reporting no insomnia^a^ | Age 48-50 | Placebo | 75 | 29%
Rigano, 2001, Italy | Percent reporting no insomnia^a^ | Age 48-50 | 0.05 mg estradiol | 88 | 80%
Rigano, 2001, Italy | Percent reporting no insomnia^a^
Rigano, 2001, Italy | Percent reporting no insomnia^a^ | Age 51-53 | Placebo | 61 | 46%
Rigano, 2001, Italy | Percent reporting no insomnia^a^ | Age 51-53 | 0.05 mg estradiol | 52 | 62%
Rigano, 2001, Italy | Percent reporting no insomnia^a^
Rigano, 2001, Italy | Percent reporting no insomnia^a^ | Age 54-56 | Placebo | 55 | 17%
Rigano, 2001, Italy | Percent reporting no insomnia^a^ | Age 54-56 | 0.05 mg estradiol | 31 | 100%

a Unclear whether 100% reported insomnia at baseline

CEE: conjugated equine estrogen; MPA: medroxyprogesterone acetate ; MSVS: moderate to severe vasomotor symptoms; WHI: Women’s Health Initiative

a difference from placebo: p=0.11

b difference from placebo: p=0.02

Table N-18 Sleep disturbance outcomes by time since menopause

Trial | Outcome | Subgroup | Treatment | N | Results
Lobo, 2009, Multinational | Difference in mean Quality of Sleep Score | < 5 yrs since menopause | Placebo | 154 | 0.2 (SD: 0.6)
Lobo, 2009, Multinational | Difference in mean Quality of Sleep Score | < 5 yrs since menopause | 0.45 mg CEE + 20 mg bazedoxifene | 162 | 0.3 (SD: 0.6)^a^
Lobo, 2009, Multinational | Difference in mean Quality of Sleep Score | < 5 yrs since menopause | 0.625 mg CEE + 20 mg bazedoxifene | 161 | 0.3 (SD: 0.6)^a^
Lobo, 2009, Multinational | Difference in mean Quality of Sleep Score
Lobo, 2009, Multinational | Difference in mean Quality of Sleep Score | ≥ 5 yrs since menopause | Placebo | 273 | 0.1 (SD: 0.7)
Lobo, 2009, Multinational | Difference in mean Quality of Sleep Score | ≥ 5 yrs since menopause | 0.45 mg CEE + 20 mg bazedoxifene | 271 | 0.2 (SD: 0.7)^a^
Lobo, 2009, Multinational | Difference in mean Quality of Sleep Score | ≥ 5 yrs since menopause | 0.625 mg CEE + 20 mg bazedoxifene | 253 | 0.3 (SD: 0.6)^b^
Utian, 2009, United States | Difference in MOS sleep score | < 5 yrs since menopause | Placebo | 40 | -6.1 (SD: 18.3)
Utian, 2009, United States | Difference in MOS sleep score | < 5 yrs since menopause | 0.45 mg CEE + 20 mg bazedoxifene | 82 | -17.7 (SD: 19.0)^c^
Utian, 2009, United States | Difference in MOS sleep score | < 5 yrs since menopause | 0.625 mg CEE + 20 mg bazedoxifene | 81 | -15.9 (SD: 19.8)^b^
Utian, 2009, United States | Difference in MOS sleep score
Utian, 2009, United States | Difference in MOS sleep score | ≥ 5 yrs since menopause | Placebo | 23 | -4.0 (SD: 16.3)
Utian, 2009, United States | Difference in MOS sleep score | ≥ 5 yrs since menopause | 0.45 mg CEE + 20 mg bazedoxifene | 45 | -11.3 (SD: 16.1)^d^
Utian, 2009, United States | Difference in MOS sleep score | ≥ 5 yrs since menopause | 0.625 mg CEE + 20 mg bazedoxifene | 47 | -11.7 (SD: 16.5)^b^

CEE: conjugated equine estrogen; MOS: Medical Outcomes Survey

a difference from placebo: p=NS

b difference from placebo: p<0.01

c difference from placebo: p<0.001

d difference from placebo: p<.0.05

## Urogenital Atrophy

Table N-19 Urogenital outcomes by time since menopause subgroups

Trial | Outcome | Subgroup | Treatment | N | Results
Osmers, 2005, Germany | Difference in MRS vaginal atrophy score from placebo | Early climacteric | Placebo | NR | -
Osmers, 2005, Germany | Difference in MRS vaginal atrophy score from placebo | Early climacteric | 40 mg black cohosh | NR | -0.07 (95% CI: -0.10 to -0.03)^a^
Osmers, 2005, Germany | Difference in MRS vaginal atrophy score from placebo
Osmers, 2005, Germany | Difference in MRS vaginal atrophy score from placebo | Late climacteric | Placebo | NR | -
Osmers, 2005, Germany | Difference in MRS vaginal atrophy score from placebo | Late climacteric | 40 mg black cohosh | NR | -0.05 (95% CI: -0.08 to -0.02)^b^

MRS: Menopausal Rating Scale; NR: not reported

a Difference from placebo: p<0.001

b Difference from placebo: p=0.001