# Short-Term Adverse Effects for Nonhormone Therapies

Table M-1a Short-term adverse effects for prescription nonhormone therapies used to treat menopausal symptoms

Study (Author, Year, Country) | Treatment (dose) | N | Total Adverse Events | Blood and Lymphatic System | Cardiac | Congenital, Familial and Genetic Disorders | Ear and Labyrinth Disorders | Eye | Endocrine Disorders | Gastrointestinal | General Disorders and Administration Site Conditions | Hepatobiliary Disorders | Immune System Disorders | Infections and Infestations
Archer, 2009, United States | placebo | 180 | | | | | | 0.0% to 1.1% | | 1.7% to 8.3% | 0.6% to 5.0%
Archer, 2009, United States | desvenlafaxine (100mg) | 182 | | | | | | 1.6% to 2.2% | | 4.9% to 45.1% | 3.8% to 11.5%
Archer, 2009, United States | desvenlafaxine (150mg) | 179 | | | | | | 5.0% to 6.1% | | 7.8% to 44.1% | 5.0% to 17.3%
Archer, 2009, United States | placebo | 151 | 105 | | | | | | | 0.7% to 7.3% | 4.0%
Archer, 2009, United States | desvenlafaxine (100mg) | 150 | 125 | | | | | 5.3% | | 6.0% to 28.7% | 12.7%
Archer, 2009, United States | desvenlafaxine (150mg) | 151 | 128 | | | | | 0.7% | | 3.3% to 21.9% | 11.3%
Speroff, 2008, United states | placebo | 77 | 67 | | | | | 0.0% to 1.3% | | 0.0% to 10.4% | 0.0% to 9.1%
Speroff, 2008, United states | desvenlafaxine (50mg) | 149 | 134 | | | | | 0.7% to 3.4% | | 4.7% to 27.5% | 3.4% to 7.4%
Speroff, 2008, United states | desvenlafaxine (100mg) | 155 | 146 | | | | | 2.6% to 5.8% | | 5.8% to 38.7% | 5.2% to 19.4%
Speroff, 2008, United states | desvenlafaxine (150mg) | 157 | 149 | | | | | 6.4% to 8.9% | | 5.7% to 47.8% | 3.8% to 17.2%
Speroff, 2008, United states | desvenlafaxine (200mg) | 151 | 147 | | | | | 6.0% to 6.6% | | 9.3% to 45.0% | 7.3% to 15.2%
Oktem, 2007, Turkey | black cohosh (40mg) | 40 | 7 | | | | | | | 0.0% to 5.0% | 2.5%
Oktem, 2007, Turkey | fluoxetine (20mg) | 40 | 13 | | | | | | | 2.5% to 5.0% | 5.0%
Bouchard, 2012, Multinational | placebo | 152 | 85 | | 5.3% | | | | | 2.6% to 4.6% | 2.0%
Bouchard, 2012, Multinational | desvenlafaxine (100mg) | 158 | 116 | | 4.4% | | | 5.7% | | 10.1% to 31.0% | 8.9%
Depomed (c), 2012, United States | placebo | 177 | 69 | | 0.6% | | | | | 0.6% to 4.0% | 0.6% to 1.7% | | | 4.0% to 5.6%
Depomed (c), 2012, United States | gabapentin (1200mg) | 174 | 150 | | | | | | | 0.6% to 6.9% | 5.2% | | | 6.3% to 8.0%
Depomed (c), 2012, United States | gabapentin (1800mg) | 181 | 173 | | | | | | | 3.9% to 8.8% | 5.0% | | | 0.6% to 6.1%
Depomed (c), 2012, United States | placebo | 183 | 31 | | | | | | | 1.6%
Depomed (c), 2012, United States | gabapentin (1200mg) | 186 | 85 | | | | | | | 3.2%
Depomed (c), 2012, United States | gabapentin (1800mg) | 190 | 72 | | | | | | | 7.4% | 0.5%
Pinkerton, 2012, Mulitinational | placebo | 1052 | 908 | 0.5% to 1.7% | 0.1% to 3.2% | 0.1% to 0.2% | 0.9% | 0.1% to 7.6% | 1.5% | 0.1% to 16.3% | 0.7% to 17.0% | 0.3% | 3.5% | 0.1% to 31.3%
Pinkerton, 2012, Mulitinational | desvenlafaxine (100mg) | 1066 | 984 | 0.8% to 1.0% | 0.1% to 3.3% | 0.3% | 4.0% | 0.2% to 15.7% | 0.7% | 0.1% to 26.2% | 0.1% to 23.5% | 0.1% to 0.3% | 2.9% | 0.1% to 38.5%
Freeman, 2011, United States | placebo | 101 | 62 | | | | | | | 5.0% to 17.8% | 9.9% to 13.9%
Freeman, 2011, United States | escitalopram (10mg) | 104 | 54 | | | | | | | 9.6% to 10.6% | 3.8% to 13.5%
Butt, 2008, Canada | placebo | 98 | | | | | 1.0% | | | | 1.0%
Butt, 2008, Canada | gabapentin (300mg) | 99 | | | | | 2.0% | 4.0% | | | 1.0% to 2.0%
Clayden, 1974, United Kingdom | placebo | 43 | | | 16.3% | | | | | 11.6% to 20.9%
Clayden, 1974, United Kingdom | clonidine (0.05 to 0.15mg) | 42 | | | 9.5% | | | | | 26.2% to 28.6%
Soares, 2010, Multinational | escitalopram (10 to 20mg) | 299 | | | | | | | | 7.0% to 20.4%
Soares, 2010, Multinational | desvenlafaxine (100 to 200mg) | 296 | | | | | | | | 8.8% to 27.7%

Blood and Lymphatic System: Anaemia Cardiac: Acute Myocardial Infarction, Angina Pectoris, Atrial Fibrillation, Coronary Artery Occlusion, Palpitation, Coronary Artery Disease Congenital, Familial and Genetic Disorders: Cerebrovascular Arteriovenous Malformation, Carotid artery occlusion Ear and Labyrinth Disorders: Vertigo Eye: Glaucoma, Narrow Anterior Chamber Angle, Retinal Haemorrhage, Abnormal vision, Mydriasis Gastrointestinal: Abdominal Pain, Colitis Ischaemic, Diverticular Perforation, Gastrooesophageal Reflux Disease, Ileus, Ileus Paralytic, Lower Gastrotintestinal Hemorrhage, Stomatitis, Swollen Tongue, Upper Gastrointestinal Hemorrhage, Flatulence, Abdominal Hernia, Gastroesophageal reflux disease exacerbation, Constipation, Diarrhea, Dry mouth, Nausea, Vomiting, Anorexia, Dyspeptic Problems General Disorders: Chest Pain, Drug Therapeutic Incompatibility, Fatigue, Non-Cardiac Chest Pain, Chills, Asthenia, Tiredness Hepatobiliary Disorders: Biliary Dyskinesia, Cholecystitis Infections and Infestations: Cellulitis, Diverticulitis, Enterocolitis Viral, Escherichia Sepsis, Herpes Zoster, Laryngitis, Pneumonia, Pyelonephrities, Subcutaneous Abscess, Urinary Tract Infection, Nasopharyngitis, Upper Respiratory Tract Infection

Note: Blank cells indicate 0 adverse events

Table M-1b Short-term adverse effects for prescription nonhormone therapies used to treat menopausal symptoms

Study (Author, Year, Country) | Treatment (dose) | N | Total Adverse Events | Investigations | Injury, poisoning and procedural complications | Metabolism/ Nutritional | Musculoskeletal | Neoplasms benign, malignant and unspecified (incl cysts and polyps) | Nervous System | Psychiatric Disorders | Renal/ Urinary | Reproductive System and Breast Disorders | Respiratory, Thoracic and Mediastinal Disorders | Skin and Subcutaneous Tissue | Vascular
Archer, 2009, United States | placebo | 180 | | | | 3.9% | | | 2.2% to 10.0% | | | | | | 3.9%
Archer, 2009, United States | desvenlafaxine (100mg) | 182 | | | | 7.1% | | | 8.2% to 19.2% | | | | | | 7.1%
Archer, 2009, United States | desvenlafaxine (150mg) | 179 | | | | 2.8% | | | 11.2% to 22.9% | | | | | | 2.8%
Archer, 2009, United States | placebo | 151 | 105 | | | | | | 0.7% to 7.3% | | | | | | 1.3%
Archer, 2009, United States | desvenlafaxine (100mg) | 150 | 125 | | | | | | 9.3% to 12.7% | | | | | | 5.3%
Archer, 2009, United States | desvenlafaxine (150mg) | 151 | 128 | | | | | | 9.3% to 11.9% | | | | | | 4.0%
Speroff, 2008, United states | placebo | 77 | 67 | | | 0.0% to 3.9% | | | 0.0% to 10.4% | | | | | 0.0% to 2.6% | 1.3%
Speroff, 2008, United states | desvenlafaxine (50mg) | 149 | 134 | | | 2.7% to 4.0% | | | 0.7% to 15.4% | | | | | 1.3% to 6.0% | 4.0%
Speroff, 2008, United states | desvenlafaxine (100mg) | 155 | 146 | | | 5.2% to 5.8% | | | 2.6% to 19.4% | | | | | 1.9% to 2.6% | 5.2%
Speroff, 2008, United states | desvenlafaxine (150mg) | 157 | 149 | | | 2.5% to 7.6% | | | 1.9% to 27.4% | | | | | 1.3% to 2.5% | 6.4%
Speroff, 2008, United states | desvenlafaxine (200mg) | 151 | 147 | | | 3.3% to 6.0% | | | 1.3% to 27.2% | | | | | 0.7% to 6.0% | 7.9%
Oktem, 2007, Turkey | black cohosh (40mg) | 40 | 7 | | | | | | 0.0% to 2.5% | | | | | 2.5%
Oktem, 2007, Turkey | fluoxetine (20mg) | 40 | 13 | | | | | | 2.5% to 7.5% | | | | | 5.0%
Bouchard, 2012, Multinational | placebo | 152 | 85 | | | | 0.7% | | 1.3% to 3.9% | | 0.7%
Bouchard, 2012, Multinational | desvenlafaxine (100mg) | 158 | 116 | | | | 3.8% | | 7.0% to 10.8% | | 0.6%
Depomed (c), 2012, United States | placebo | 177 | 69 | 2.3% | | | 5.1% | | 0.6% to 5.6%
Depomed (c), 2012, United States | gabapentin (1200mg) | 174 | 150 | 2.9% | | | 2.3% | 0.6% | 8.6% to 23.6% | | | | 0.6%
Depomed (c), 2012, United States | gabapentin (1800mg) | 181 | 173 | 5.0% | 0.6% | | 2.8% | 0.6% | 0.6% to 19.3%
Depomed (c), 2012, United States | placebo | 183 | 31 | | 0.5% | | | | 0.5% to 7.7%
Depomed (c), 2012, United States | gabapentin (1200mg) | 186 | 85 | | 0.5% | | | 0.5% | 4.8% to 17.2%
Depomed (c), 2012, United States | gabapentin (1800mg) | 190 | 72 | | 0.5% | | | | 1.6% to 18.9%
Pinkerton, 2012, Mulitinational | placebo | 1052 | 908 | 0.1% to 9.7% | 0.1% to 20.2% | 0.1% to 4.2% | 0.2% to 34.2% | 0.1% to 1.0% | 0.1% to 24.9% | 23.0% | | 0.1% to 11.8% | 0.4% to 19.6% | 0.1% to 11.5% | 3.1% to 6.0%
Pinkerton, 2012, Mulitinational | desvenlafaxine (100mg) | 1066 | 984 | 0.1% to 12.4% | 0.0% to 22.0% | 0.2% to 7.1% | 0.1% to 27.8% | 0.1% to 1.4% | 0.1% to 31.1% | 0.2% to 43.8% | 0.1% | 0.1% to 9.8% | 0.1% to 25.3% | 0.2% to 15.7% | 3.6% to 10.1%
Freeman, 2011, United States | placebo | 101 | 62 | 4.0% | | | | | 6.9% to 10.9% | | | | | 8.9%
Freeman, 2011, United States | escitalopram (10mg) | 104 | 54 | 5.8% | | | | | 2.9% to 8.7% | | | | | 6.7%
Butt, 2008, Canada | placebo | 98 | | | | | | | 1.0% to 36.7%
Butt, 2008, Canada | gabapentin (300mg) | 99 | | | | | | | 2.0% to 25.3%
Clayden, 1974, United Kingdom | placebo | 43 | | | | | 11.6% | | 51.2% | | | 2.3% | | 9.3%
Clayden, 1974, United Kingdom | clonidine (0.05 to 0.15mg) | 42 | | | | | 11.9% | | 52.4% | | | 2.4% | | 16.7%
Soares, 2010, Multinational | escitalopram (10 to 20mg) | 299 | | | | | | | 9.4% to 28.4% | | | | | 11.0%
Soares, 2010, Multinational | desvenlafaxine (100 to 200mg) | 296 | | | | | | | 11.1% to 25.7% | | | | | 14.5%

Investigations: Weight Increased, Blood Creatine Phosphokinase MB Increased, Blood Pressure Increased, Cardiac Stress Test Abnormal, Electrocardiogram T Wave Abnormal, Electrocardiogram T Wave Inversion, Electrocardiogram Abnormal Injury, poisoning and procedural complications: Overdose; Attempted Suicide, Accidental Overdose, Road Traffic Accident, Meniscus Lesion, Rib Fracture, Drug Toxicity, Hand Fracture, Injury, Intentional Overdose, Limb Injury, Patella Fracture, Radius Fracture, Traumatic Intracranial Hemorrhage, Ulna Fracture Metabolism/Nutritional: Weight Gain, Hypercholesteremia, Hyperlipemia, Hypokalaemia Musculoskeletal and Connective Tissue: Arthralgia, Back Pain, Bunion, Flank Pain, Foot Deformity, Intervertebral Disc Protrusion, Knee Deformity, Musculoskeletal Chest Pain, Osteoarthritis, Pain in Extremity Neoplasms benign, malignant and unspecified (incl cysts and polyps): Breast Cancer, Basal Cell Carcinoma, Carcinoid Tumor Pulmonary, Dermatofibrosarcoma, Lung Adenocarcinoma, Malignant Lung Neoplasm, Malignant Melanoma In Situ, Multiple Myeloma, Non-Small Cell Lung Cancer Stage III, Ovarian Cancer, Ovarian Cancer Recurrent, Pancreatic Carcinoma Metastatic, Squamous Cell Carcinoma of Skin, Thyroid Cancer, Transitional Cell Carcinoma, Uterine Leiomyoma Nervous System: Ageusia, Cerebral Hematoma, Cerebrovascular Disorder, Cervical Myelopathy, Confusion, Convulsion, Dizziness, Dysarthria, Headache, Hypoaesthesia, Insomnia, Irritability, Libido Decrease, Migraine, Nerve Compression, Nervousness, Paraesthesia, Presyncope, Sedation, Somnolence, Thinking Abnormal, Transient Ischemic Attack Psychiatric Disorders: Major Depression, Mental Status Changes Reproductive System and Breast Disorders: Endometrial Hyperplasia Respiratory, Thoracic and Mediastinal Disorders: Acute Resperatory Failure, Asthma, Chronic Obstructive Pulmonary Disease, Non-Cardiogenic Pulmonary Edema, Pulmonary Embolism, Pneumothorax Renal/ Urinary: Leukorrhea, Nephrolithiasis, Renal Failure Acute Skin and Subcutaneous Tissue: Sweating, Rash, Allergic Skin Reaction, Erythema, Pruritus Vascular: Hypertension

Note: Blank cells indicate 0 adverse events

Table M-2a Short-term adverse effects for nonprescription nonhormone therapies used to treat menopausal symptoms

Study (Author, Year, Country) | Treatment (dose), n | N | Individuals with adverse events | Total Adverse Events | Blood and Lymphatic System | Cardiac | Ear and Labyrinth | Endocrine | Eye | Gastrointestinal | General Disorders and Administration Site Conditions | Immune | Infections
Evans, 2011, Canada | Placebo | 42 | 33 | 79 | | | | | | 0.0% to 14.3%
Evans, 2011, Canada | Genistein (30mg) | 41 | 29 | 72 | | | | | | 0.0% to 9.8%
Garcia, 2010, Multinational | Placebo | 31 | 9 | 34 | | | | | | 6.5% | 6.5% | | 3.2%
Garcia, 2010, Multinational | Nutrafem [multibotanical] | 103 | 43 | 109 | | | 1.0% | | | 9.7% | 5.8% | 1.9% | 1.9%
Chandeying, 2007, Thailand | CEE + MPA (0.625mg E + 2.5mg P) | 30 | | 34 | | 3.3% | | | | 0.0% to 6.7%
Chandeying, 2007, Thailand | Pueraria mirifica (50 mg) | 30 | | 31 | | 6.7% | | | | 0.0% to 10.0% | 3.3%
Newton, 2006, United States | Placebo | 84 | | 67 | | | | | | 15.5% | 9.5%
Newton, 2006, United States | CEE + MPA (0.625mg E + 2.5mg P) | 32 | | 41 | | | | | | 12.5% | 18.8%
Newton, 2006, United States | Black cohosh (160 mg) | 80 | | 57 | | | | | | 15.0% | 15.0%
Newton, 2006, United States | ProGyne multibotanical w/ black cohosh (200 mg) + 9 other ingredients | 76 | | 44 | | | | | | 14.5% | 9.2%
Newton, 2006, United States | ProGyne multibotanical + dietary soy counseling | 79 | | 57 | | | | | | 10.1% | 15.2%
Heger, 2006, Ukraine | Placebo | 55 | 8
Heger, 2006, Ukraine | Phytoestrol N [rheum rhaponticum] (4 mg) | 54 | 8 | | | 1.9% | | | | 1.9%
Tice, 2003, United States | Placebo | 85 | | 33 | | | | | | 3.5% to 4.7%
Tice, 2003, United States | Rimostil (57.2 mg) | 83 | | 28 | | | | | | 3.6% to 9.6%
Tice, 2003, United States | Promensil (82 mg) | 84 | | 31 | | | | | | 2.4% to 4.8%
Albertazzi, 1998, Italy | Placebo | 53 | | 45 | | | | | | 1.9% to 50.9%
Albertazzi, 1998, Italy | Isoflavones [soy protein] (76 mg) | 51 | | 35 | | | | | | 0.0% to 49.0%
de Sousa-Munoz, 2009, Brazil | Placebo | 42 | 7 | 16 | 2.4% | | | | | 0.0% to 7.1%
de Sousa-Munoz, 2009, Brazil | Isoflavones (120 mg) | 42 | 12 | 22 | | | | | 2.4% | 0.0% to 4.8%
Uebelhack, 2006, Germany | Placebo | 150 | | 32 | 0.7% | | 0.7% | | 1.3% | 0.7% | | | 10.7%
Uebelhack, 2006, Germany | St. John's Wort (70 mg) + black cohosh (3.75 mg) | 151 | | 35 | | | | | 0.7% | 0.7% | 0.7% | | 11.9%
Kotsopoulos, 2000, Australia | Placebo | 50 | | 9 | | | | | | 4.0% | 12.0% | 2.0%
Kotsopoulos, 2000, Australia | Isoflavones [daidzein, genistein, glycitein] (118 mg) | 44 | | 10 | | | | | | | 15.9%
Panjari, 2009, Australia | Placebo | 43 | | 24
Panjari, 2009, Australia | DHEA (50 mg) | 46 | | 31
Ho, 2007, Hong Kong | Placebo | 91 | 43 | 68 | | | 1.1% | 3.3% | | 3.3% to 11.0% | 3.3%
Ho, 2007, Hong Kong | Isoflavones [soy] (80 mg) | 85 | 58 | 103 | | | 1.2% | 2.4% | 2.4% | 3.5% to 16.5% | 2.4%
Osmers, 2005, Germany | Placebo | 151 | | 47 | 0.7% | | 0.7% | | | 4.6% | 0.7% | | 12.6%
Osmers, 2005, Germany | Remifemin [black cohosh] (40 mg) | 153 | | 50 | 0.7% | 1.3% | | | | 5.2% | 0.7% | | 8.5%
Levis, 2011, United States | Placebo | 126 | 121 | | 0.8% to 15.1% | | | | | 9.5% to 42.9%
Levis, 2011, United States | Novasoy [soy protein] (200 mg) | 122 | 122 | | 0.8% to 15.6% | | | | | 17.2% to 52.5%
Radhakrishnan, 2009, India | Placebo | 41 | | 27 | | | | | | 0.0% to 34.1% | 2.4%
Radhakrishnan, 2009, India | Isoflavones [soy protein] (75 mg) | 44 | | 33 | | | | | | 2.3% to 34.1% | 6.8%
Plotnikoff, 2011, United States | placebo | 59 | | | | | | | | 1.7%
Plotnikoff, 2011, United States | keishibukuryogab (7.5g) | 62 | | | | | | | | 22.6%
Plotnikoff, 2011, United States | keishibukuryogab (12.5g) | 57 | | | | | | | | 19.3%

Blood and Lymphatic System: Anemia, Leukemia, Leg Edema Cardiac: Palpitation, Cardiomyopathy Ear and Labyrinth: Hearing Endocrine: Thyroid Eye: Blurred Vision, Swollen Eye Gastrointestinal: Anorexia, Bloating, Heartburn, Constipation, Diarrhea, Dry mouth, Nausea, Vomiting, Nausea/ Vomiting, Epigastric Pain, Stomach/GI Ache or Upset, Duodenal Ulcer, Flatulence General Disorders and Administration Site Conditions: Drowsiness/Tiredness, Weakness, Unpalatable/intolerable

Note: Blank cells indicate 0 adverse events

Table M-2b Short-term adverse effects for nonprescription nonhormone therapies used to treat menopausal symptoms

Study (Author, Year, Country) | Treatment (dose), n | N | Individuals with adverse events | Total Adverse Events | Injury, Posoning, or Procedural Complications | Investigations | Metabolism/Nutritional | Musculoskeletal | Neoplasms | Nervous System | Psychiatric | Renal/ Urinary | Reproductive System/Breast | Respiratory and Thoracic | Skin and Subcutaneous Tissue | Surgical and Medical Procedures | Vascular | Other
Evans, 2011, Canada | Placebo | 42 | 33 | 79 | | | | | | 2.4% | 2.4% | | 0.0% to 7.1%
Evans, 2011, Canada | Genistein (30mg) | 41 | 29 | 72 | | | | | | 0.0% to 2.4% | | 2.4% | 2.4% to 9.8% | | 2.4%
Garcia, 2010, Multinational | Placebo | 31 | 9 | 34 | | | | 12.9% | | 9.7% | | | 3.2% | 12.9% | 9.7% | 3.2%
Garcia, 2010, Multinational | Nutrafem [multibotanical] | 103 | 43 | 109 | | 2.9% | | 9.7% | | 12.6% | | | 1.0% | 17.5% | 1.9% | 1.9%
Chandeying, 2007, Thailand | CEE + MPA (0.625mg E + 2.5mg P) | 30 | | 34 | | | 10.0% | | | 0.0% to 6.7% | | 3.3% | 0.0% to 30.0% | 10.0% | 6.7% | | | 3.3% to 6.7%
Chandeying, 2007, Thailand | Pueraria mirifica (50 mg) | 30 | | 31 | | | | 3.3% | | 0.0% to 20.0% | | | 6.7% to 16.7% | 6.7% | 3.3%
Newton, 2006, United States | Placebo | 84 | | 67 | | | | 11.9% | | 19.0% | | | 3.6% to 20.2%
Newton, 2006, United States | CEE + MPA (0.625mg E + 2.5mg P) | 32 | | 41 | | | | 3.1% | | 18.8% | | | 15.6% to 59.4%
Newton, 2006, United States | Black cohosh (160 mg) | 80 | | 57 | | | | 13.8% | | 15.0% | | | 0.0% to 12.5%
Newton, 2006, United States | ProGyne multibotanical w/ black cohosh (200 mg) + 9 other ingredients | 76 | | 44 | | | | 11.8% | | 10.5% | | | 1.3% to 10.5%
Newton, 2006, United States | ProGyne multibotanical + dietary soy counseling | 79 | | 57 | | | | 11.4% | | 15.2% | | | 2.5% to 17.7%
Heger, 2006, Ukraine | Placebo | 55 | 8 | | | | 1.8% | 1.8% | | | | 1.8% | 0.0% to 3.6% | 1.8% | | | | 1.8%
Heger, 2006, Ukraine | Phytoestrol N [rheum rhaponticum] (4 mg) | 54 | 8 | | | | 1.9% | 1.9% | | 1.9% | | | 0.0% to 1.9% | 1.9%
Tice, 2003, United States | Placebo | 85 | | 33 | | | | 15.3% | | 12.9% | | | | 16.5%
Tice, 2003, United States | Rimostil (57.2 mg) | 83 | | 28 | | | | 18.1% | | 4.8% | | | | 12.0%
Tice, 2003, United States | Promensil (82 mg) | 84 | | 31 | | | | 17.9% | | 6.0% | | | | 10.7%
Albertazzi, 1998, Italy | Placebo | 53 | | 45 | | | | | | | | | | | | | | 17.0%
Albertazzi, 1998, Italy | Isoflavones [soy protein] (76 mg) | 51 | | 35 | | | | | | | | | | | | | | 5.9%
de Sousa-Munoz, 2009, Brazil | Placebo | 42 | 7 | 16 | | | 4.8% | 7.1% | | 0.0% to 4.8%
de Sousa-Munoz, 2009, Brazil | Isoflavones (120 mg) | 42 | 12 | 22 | | | 2.4% | 4.8% | | 2.4% to 4.8% | | | 2.4% | | | | | 7.1%
Uebelhack, 2006, Germany | Placebo | 150 | | 32 | 1.3% | 2.0% | | 3.3% | | | | | 0.7%
Uebelhack, 2006, Germany | St. John's Wort (70 mg) + black cohosh (3.75 mg) | 151 | | 35 | 1.3% | 2.0% | 1.3% | 4.0% | | 0.7%
Kotsopoulos, 2000, Australia | Placebo | 50 | | 9
Kotsopoulos, 2000, Australia | Isoflavones [daidzein, genistein, glycitein] (118 mg) | 44 | | 10 | | | 2.3% | | | | | | | | | | | 2.3%
Panjari, 2009, Australia | Placebo | 43 | | 24 | | | | | | | | | | | | | | 55.8%
Panjari, 2009, Australia | DHEA (50 mg) | 46 | | 31 | | | | | | | | | | | | | | 4.3% to 56.5%
Ho, 2007, Hong Kong | Placebo | 91 | 43 | 68 | | | 2.2% to 3.3% | 4.4% to 8.8% | 1.1% | 4.4% | | | 2.2% | 2.2% | 2.2% | | 1.1% to 2.2% | 2.2% to 4.4%
Ho, 2007, Hong Kong | Isoflavones [soy] (80 mg) | 85 | 58 | 103 | | | 3.5% to 7.1% | 3.5% to 20.0% | | 1.2% to 9.4% | | | 3.5% to 4.7% | 2.4% | 2.4% | | 1.2% to 4.7% | 1.2% to 8.2%
Osmers, 2005, Germany | Placebo | 151 | | 47 | | 3.3% | | 6.6% | | 3.3% | 3.3% | | 2.6% | 0.7% | 2.0% | | 0.7%
Osmers, 2005, Germany | Remifemin [black cohosh] (40 mg) | 153 | | 50 | 1.3% | 3.9% | 1.3% | 9.8% | | 2.6% | 1.3% | 0.7% | 2.6% | | 2.0% | | 0.7%
Levis, 2011, United States | Placebo | 126 | 121 | | | | | 0.8% to 5.6% | 0.8% | 34.1% | | 4.0% | 4.8% to 23.8% | 4.0% | | | 4.0% | 7.1% to 34.1%
Levis, 2011, United States | Novasoy [soy protein] (200 mg) | 122 | 122 | | | | | 4.9% to 5.7% | 0.8% | 44.3% | | 5.7% | 7.4% to 25.4% | 5.7% | | | 4.1% | 2.5% to 32.0%
Radhakrishnan, 2009, India | Placebo | 41 | | 27 | | | | | | | | | | | 4.9%
Radhakrishnan, 2009, India | Isoflavones [soy protein] (75 mg) | 44 | | 33 | | | | | | | | | | | 4.5%
Plotnikoff, 2011, United States | placebo | 59
Plotnikoff, 2011, United States | keishibukuryogab (7.5g) | 62
Plotnikoff, 2011, United States | keishibukuryogab (12.5g) | 57

Immune: Immune Disorders, Allergies Metabolism/Nutritional: Appetite Increase, Weight Gain, Hunger Musculoskeletal: Musculoskeletal spasm/numbness, Fracture, Back Pain, Myalgia/ Arthralgia Nervous System: Dizziness, Insomnia, Headache, Nervous Disorders, Memory, Sole/Palm Numb, Intercostal Neuralgia, Tremors Psychiatric: Increased Emotionality Renal/ Urinary: Renal/ Urinary, UTI, Dysuria, Nocturia, Freq Urination Reproductive System/Breast: Breast soreness, Abnormal Mammogram, Reproductive System/Breast, Mastodynia, Cramps, Vaginal bleeding/Spotting, Vaginal Odor, Uterofibroma, Endometrium Dysplasia, Cervical Dysplasia, Pelvic Discomfort, Menstrual Disorder Respiratory and Thoracic: Upper RTI, Chest Discomfort Skin and Subcutaneous Tissue: Bruisability, Itching, Skin Disorders Vascular: Vascular Disorders, Hypertension, Hemorrhoids Other: Lower extremity weakness, Lower Extremity Tenderness, Abdominal pain, Acute Appendicitis, Sweating, Hand Sweats, Nonandrogeneic Aes, Increased Facial Hair, Hair Loss

Note: Blank cells indicate 0 adverse events