# Quality Assessments From Nelson Report

Table L-1a Quality assessment for articles reporting long term effects of hormone therapies

Study/Trial | Adequate randomizationn | Adequate concealment | Groups similar at baseline | Comparable groups maintained | Eligibility criteria specified | Outcome assessors masked | Care provider maskedHE | Patient masked
Anderson 2003}/WHI estrogen plus progestin | Y | Y | Y | Compliance similar | Y | Y | Y | Y
Anderson 2004 /WHI estrogen only | Y | Y | Y | Y | Y | Y | Y | Y
Cherry 2002/ESPRIT | Y | Y | Y | Greater noncompliance in treatment group | Y | Y | Y | Y
Chlebowski 2010/WHI estrogen plus progestin | Y | Y | Y | Y | Y | Y | Y | Y
Cirillo 2005/WHI estrogen plus progestin | Y | Y | Y | Y | Y | Y | Y | Y
Heiss 2008/WHI estrogen plus progestin | Y | Y | Y | Y | Y | Y | Y | Y
Hulley 2002/HERS and HERS II | Y | Y | Y | Y | Y | Y | Y | Y
LaCroix 2011/WHI estrogen only | Y | Y | Y | Y | Y | Y | Y | Y
Rossouw 2002/WHI estrogen plus progestin | Y | Y | Y | Y | Y | Y | Y | Y

Table L1-b1 Quality assessment for articles reporting long term effects of hormone therapies

Study/Trial | Attrition, crossovers, adherence, and contamination reported | Differential loss to followup | Intention to treat analysis | Post-randomization exclusions | Outcomes prespecified | Funding source | External validity | Study Quality
Anderson 2003/WHI estrogen/ progestin | Y | N | Y | Not reported | Y | National Heart, Lung, and Blood Institute, US Dept of Health and Human Services | Good | Fair
Anderson 2004 /WHI estrogen only | Y | N | Y | N | Y | National Heart, Lung, and Blood Institute, US Dept of Health and Human Services | Good | Fair
Cherry 2002/ESPRIT | Unclear | Unclear | Y | Not reported | Y | Schering AG | Fair | Fair
Chlebowski 2010/WHI estrogen/ progestin | Y | N | Y | N | Y | National Heart, Lung, and Blood Institute, US Dept of Health and Human Services | Good | Fair
Cirillo 2005/WHI estrogen/ progestin | Y | N | Y | N | Y | National Heart, Lung, and Blood Institute, US Dept of Health and Human Services | Good | Fair
Heiss 2008/WHI estrogen/ progestin | Y | N | Y | N | Y | National Heart, Lung, and Blood Institute, US Dept of Health and Human Services | Good | Fair
Hulley 2002/HERS and HERS II | Y | N | Y | Y | Y | Wyeth-Ayerst Research | Good/Fair | Fair
LaCroix 2011/WHI estrogen only | Y | N | Y | N | Y | National Heart, Lung, and Blood Institute, US Dept of Health and Human Services | Good | Fair
Rossouw 2002/WHI estrogen/ progestin | Y | N | Y | N | Y | National Heart, Lung, and Blood Institute, US Dept of Health and Human Services | Good | Fair