# Urogenital Atrophy Supplemental Plots

Figure J-1 Urogenital atrophy and symptoms forest plot of pairwise comparisons—vaginal estrogens compared with placebo (excludes Dessole 2004 as outlier)

Figure J-1 is a forest plot for the pairwise comparison of vaginal estrogens compared with placebo (N=12 trials) on urogenital atrophy, Key Question 1. Eight of the trials showed statistically significant improvements in urogenital aatropy, while four of the trials had 95 percent confidence intervals including zero. The pooled SMD is -0.44 (95% CI: -0.65 to -0.23).

Figure J-2 Urogenital atrophy and symptoms forest plot of pairwise comparisons—vaginal estrogens compared with placebo (includes Dessole 2004)

Figure J-2 is a forest plot for the pairwise comparison of vaginal estrogens compared with placebo, including one trial with a very high point estimate of -2.00 (N=13 trials) on urogenital atrophy, Key Question 1. Nine of the trials showed statistically significant improvements in urogenital aatropy, while four of the trials had 95 percent confidence intervals including zero. The pooled SMD is -0.54 (95% CI: -0.77 to -0.31).

Figure J-3 Urogenital atrophy and symptoms forest plot of pairwise comparisons—ospemifene compared with placebo

Figure J-3 is a forest plot for the pairwise comparison of ospemifene compared with placebo (N=3 trials) on urogenital atrophy, Key Question 1. All three of the trials showed statistically significant improvements in urogenital atrophy. The pooled SMD is -0.75 (95% CI: -1.05 to -0.45).

Figure J-4 Urogenital atrophy forest plot of pairwise comparisons—nonvaginal standard dose estrogens compared with placebo

Figure J-4 is a forest plot for the pairwise comparison of nonvaginal standard dose estrogens compared with placebo (N=6 trials) on urogenital atrophy, Key Question 1. Four of the six trials showed statistically significant improvements in urogental atrophy, while two trials had 95 percent confidence intervals including zero. The pooled SMD is -0.32 (95% CI: -0.47 to -0.18).

Figure J-5 Urogenital atrophy forest plot of pairwise comparisons—nonvaginal low/ultralow dose estrogens compared with placebo

Figure J-5 is a forest plot for the pairwise comparison of nonvaginal low/ultralow dose estrogens compared with placebo (N=8 trials) on urogenital atrophy, Key Question 1. Seven of the eight trials showed statistically significant improvements in urogental atrophy, while one trial had a 95 percent confidence interval including zero. The pooled SMD is -0.41 (95% CI: -0.53 to -0.30).

Figure J-6 Urogenital atrophy forest plot of pairwise comparisons—isoflavones with placebo

Figure J-6 is a forest plot for the pairwise comparison of isoflavones compared with placebo (N=5 trials) on urogenital atrophy, Key Question 1. Three of the trials showed statistically significant improvements while two of the trials had 95 percent confidence intervals including zero. The pooled SMD is -0.48 (95% CI: -0.77 to -0.18).