# Sexual Function Plots

Figure I-1 Pain during sex—vaginal estrogens compared with placebo

Figure I-1 is a forest plot for the pairwise comparison of vaginal estrogens compared with placebo (N=10 trials) on pain domain of sexual function, Key Question 1. Seven of the 10 trials showed statistically signifcant reductions in pain. The pooled SMD is -0.53 (95% CI: -0.74 to -0.34).

Figure I-2 Pain during sex—oral estrogen compared with placebo

Figure I-2 is a forest plot for the pairwise comparison of oral estrogens compared with placebo (N=4 trials) on the pain domain of sexual function, Key Question 1. Two of the four trials had 95 percent confidence intervals including zero. The pooled SMD is -0.22 (95% CI: -0.35 to -0.09).B82

Figure I-3 Pain during sex—all estrogens compared with placebo

Figure I-3 is a forest plot for the pairwise comparison of all estrogens compared with placebo (N=14 trials) on the pain domain of sexual function, Key Question 1. Six of the 14 trials did not show statistically significant reductions in pain. The pooled SMD is -0.45 (95% CI: -0.61 to -0.29).

Figure I-4 Global assessment of sexual function—all estrogens compared with placebo

Figure I-4 is a forest plot for the pairwise comparison of all estrogens compared with placebo (N=15 trials) on overall sexual function, Key Question 1. All 15 trials had positive point estimates indicating an improvement in overall sexual function, though seven of the 15 trials had 95 percent confidence intervals including zero. The pooled SMD is 0.27 (95% CI: 0.19 to 0.35).

Figure I-5 Global assessment of sexual function—SSRI/SNRI compared with placebo

Figure I-5 is a forest plot for the pairwise comparison of SSRI/SNRIs compared with placebo (N=2 trials) on overall sexual function, Key Question 1. Both trials had point estimates showing improvement in sexual function, though the 95 percent confidence intervals for the trials included zero. The pooled SMD is 0.27 (95% CI: 0.01 to 0.52).

Figure I-6 Global assessment of sexual function—isoflavones compared with placebo

Figure I-6 is a forest plot for the pairwise comparison of isoflavones compared with placebo (N=4 trials) on overall sexual function, Key Question 1. The 95 percent confidence intervals for three of the four trials included zero. The pooled SMD is 0.24 (95% CI: -0.12 to 0.61).

Figure I-7 Sexual interest—all estrogens compared with placebo

Figure I-B897 is a forest plot for the pairwise comparison of any estrogen compared with placebo (N=7 trials) on the interest domain of sexual function, Key Question 1. All of the trials had a positive point estimate indicating improvement, though 95 percent confidence intervals for six of the seven trials included zero. The pooled SMD is 0.18 (95% CI: 0.09 to 0.26).

Figure I-8 Sexual interest—SNRI compared with placebo

Figure I-8 is a forest plot for the pairwise comparison of SNRIs compared with placebo (N=2 trials) on the interest domain of sexual function, Key Question 1. Both trials had positive point estimates indicating improvement, but the 95 percent confidence interval for one of the trials included zero. The pooled SMD is 0.16 (95% CI: -0.07 to 0.39).

Figure I-9 Sexual interest—isoflavones compared with placebo

Figure I-9 is a forest plot for the pairwise comparison of isoflavones compared with placebo (N=5 trials) on the interest domain of sexual function, Key Question 1. Four trials had a positive point estimate indicating improvement; however, three trials have 95 percent confidence intervals including zero. The pooled SMD is 0.26 (95% CI: 0.00 to 0.52).

Figure I-10 Mean difference in satisfying sexual episodes over 4 weeks—testosterone compared with placebo in women with intact uteri

Figure I-10 is a forest plot for testosterone compared with placebo (N=4 trials) on mean difference in satisfying sexual episodes per month among women with intact uteri, Key Question 1. Three of the four trials showed statistically significant increases in satisfying sexual episodes per month. The pooled mean difference is 1.1 (95% CI: 0.64 to 1.4).

Figure I-11 Mean difference in satisfying sexual episodes over 4 weeks—testosterone compared with placebo in women with and without intact uteri/ovaries

Figure I-11 is a forest plot for the pairwise comparison of testosterone compared with placebo (N=4 trials) on mean difference in satisfying sexual episodes per month in trials combining women with and without intact uteri, Key Question 1. Three of the four trials showed statistically significant increases in satisfying sexual episodes per month. The pooled mean difference is 1.31 (95% CI: 0.89 to 1.7).

Figure I-12 Mean difference in satisfying sexual episodes over 4 weeks—testosterone compared with placebo (all trials)

Figure I-12 is a forest plot for the pairwise comparison of all testosterone compared with placebo trials (N=8) on mean difference of satisfying sexual episodes per month, Key Question 1. Six of the eight trials showed statistically significant increases in mean difference of satisfying sexual episodes per month. The pooled mean difference is 1.17 (95% CI: 0.88 to 1.5).