# Psychological Symptoms Supplemental Tables and Plots

Figure H-1 Global psychological well-being—SSRI/SNRI compared with placebo

Figure H-1 is a forest plot for the pairwise comparison of SSRI/SNRIs compared with placebo (N=6 trials) on global mental health, Key Question 1. Five of the six trials showed significant reductions (improvements) in global mental health scores. The pooled SMD is -0.42 (95% CI: -0.60 to -0.24).

Figure H-2 Depressive symptoms—SSRI/SNRI compared with placebo

Figure H-2 is a forest plot for the pairwise comparison of SSRI/SNRIs compared with placebo (N=5 trials) on depressive symptoms, Key Question 1. Four of the five trials showed significant reductions (improvements) in depressive symptom scores, and the other trial had a negative point estimate, though not significant. The pooled SMD is -0.43 (95% CI: -0.60 to -0.26).B66

Figure H-3 Anxiety symptoms—SNRI compared with placebo

Figure H-3 is a forest plot for the pairwise comparison of SSRI/SNRIs compared with placebo (N=3 trials) on anxiety symptoms, Key Question 1. All three trials showed significant reductions (improvements) in anxiety symptom scores. The pooled SMD is -0.31 (95% CI: -0.50 to -0.12).

Figure H-4 Global psychological well-being—estrogen compared with placebo

Figure H-4 is a forest plot for the pairwise comparison of estrogens compared with placebo (N=14 trials) on global mental health, Key Question 1. Two trials had positive point estimates, one trial had a point estimate of zero, and the remaining trials had negative point estimates (indicating improvement). The pooled SMD is -0.26 (95% CI: -0.40 to -0.13).

Figure H-5 Depressive symptoms—estrogen compared with placebo

Figure H-5 is a forest plot for the pairwise comparison of estrogens compared with placebo (N=18 trials) on depressive symptoms, Key Question 1. Two trials had positive point estimates, two trials had point estimates of zero, and the remaining trials showed significant reductions in depressive symptoms. The pooled SMD is -0.36 (95% CI: -0.53 to -0.20).

Figure H-6 Anxiety symptoms—estrogen compared with placebo

Figure H-6 is a forest plot for the pairwise comparison of estrogens compared with placebo (N=13 trials) on anxiety symptoms, Key Question 1. One trial had a positive point estimate, eight trials had negative point estimates but were not significant, and four trials showed significant reductions in anxiety symptoms. The pooled SMD is -0.34 (95% CI: -0.50 to -0.18).

Figure H-7 Global psychological well-being—gabapentin compared with placebo

Figure H-7 is a forest plot for the pairwise comparison of gabapentin compared with placebo (N=2 trials) on global mental health, Key Question 1. Neither of the trials showed significant improvements in global mental health. The pooled SMD is -0.23 (95% CI: -0.48 to 0.02).

Figure H-8 Global psychological well-being—isoflavones compared with placebo

Figure H-8 is a forest plot for the pairwise comparison of isoflavones compared with placebo (N=7 trials) on global mental health, Key Question 1. All point estimates were less than zero (indicating improvements), but none of the trials showed statistically significant improvements in global mental health. The pooled SMD is -0.11 (95% CI: -0.22 to 0.01).

Figure H-9 Depressive symptoms—isoflavones compared with placebo

Figure H-9 is a forest plot for the pairwise comparison of isoflavones compared with placebo (N=9 trials) on depressive symptoms, Key Question 1. Two point estimates were zero, with the remaining point estimates less than zero (indicating improvements), though six of the nine trials had 95 percent confidence intervals including zero. The pooled SMD is -0.29 (95% CI: -0.49 to -0.09).

Figure H-10 Anxiety symptoms—isoflavones compared with placebo

Figure H-10 is a forest plot for the pairwise comparison of isoflavones compared with placebo (N=7 trials) on anxiety symptoms, Key Question 1. One point estimate was zero, with the remaining six point estimates less than zero (indicating improvements). Five of the seven trials had 95 percent confidence intervals including zero. The pooled SMD is -0.30 (95% CI: -0.46 to -0.14).

Table H-1 All pairwise psychological outcome SMDs for global psychological well-being

SSRI/SNRI
| E-High
| 0.17 (-0.03 to 0.38) tau^2^=0.00; n=1 | E-Standard
| 0.14 (-0.17 to 0.45) tau^2^=0.00; n=1 | -0.06 (-0.14 to 0.02) tau^2^=0.00; n=9 | E-Low Ultralow
| | | | Gababentin
| | | | | Isoflavones
-0.42 (-0.60 to -0.24) tau^2^=0.03; n=6 | -0.43 (-0.66 to -0.19) tau^2^=0.00; n=1 | -0.10 (-0.18 to -0.03) tau^2^=0.00;n=12^a^ | -0.17 (-0.35 to 0.02) tau^2^=0.06; n=9 | -0.23 (-0.48 to 0.02) tau^2^=0.00; n=2 | -0.11 (-0.22 to 0.01) tau^2^=0.00; n=7 | Placebo

a Excluding two large prevention trials -0.22 (-0.35 to -0.08) tau2=0.02; n=10

Table H-2 All pairwise psychological outcome SMDs for depression symptoms

SSRI/SNRI
| E-High
| NS | E-Standard
| 0.00 (-0.31 to 0.31) tau^2^=0.00; n=1 | -0.21 (-0.44 to 0.02) tau^2^=0.00; n=2 | E-Low Ultralow
| | | | Isoflavones
-0.43 (-0.60 to -0.26) tau^2^=0.02; n=5 | -0.41 (-0.57 to -0.25) tau^2^=0.00; n=4 | -0.31 (-0.48 to -0.15) tau^2^=0.05;n=12^a^ | -0.12 (-0.42 to 0.18) tau^2^=0.03; n=4 | -0.29 (-0.49 to -0.09) tau^2^=0.05; n=9 | Placebo

a Excluding two large prevention trials -0.41 (-0.67 to -0.16) tau2=0.12; n=10

Table H-3 All pairwise psychological outcome SMDs for anxiety symptoms

SSRI/SNRI
| E-High
| -0.03 (-0.22 to 0.17) tau^2^=0.00; n=1 | E-Standard
| 0.31 (0.00 to 0.63) tau^2^=0.00; n=1 | -0.16 (-0.60 to 0.28) tau^2^=0.00; n=1 | E-Low Ultralow
| | | | Isoflavones
-0.31 (-0.50 to -0.12) tau^2^=0.02; n=3 | -0.35 (-0.60 to -0.10) tau^2^=0.01; n=2 | -0.31 (-0.55 to -0.06) tau^2^=0.11;n=9^a^ | -0.25 (-0.53 to 0.04) tau^2^=0.00; n=3 | -0.30 (-0.46 to -0.14) tau^2^=0.01; n=7 | Placebo

a Excluding one large prevention trials -0.37 (-0.61 to -0.12) tau2=0.09; n=8