# Vasomotor Symptom Supplemental Tables and Plots

Figure F-1 Vasomotor symptoms forest plot of pairwise comparisons—estrogen (high dose) compared with placebo

Figure F-1 is a forest plot for the pairwise comparison of high dose estrogens compared with placebo (N=9 trials) for vasomotor symptoms, Key Question 1. All nine trials showed significant improvements individually, with a pooled SMD of -0.50 (95% CI: -0.61 to -0.39).

Figure F-2 Vasomotor symptoms forest plot of pairwise comparisons—estrogen (standard dose) compared with placebo

Figure F-2 is a forest plot for the pairwise comparison of standard dose estrogens compared with placebo (N=39 trials) for vasomotor symptoms, Key Question 1. Three trials had 95% confidence intervals including zero, with the remaining 36 trials showing significant improvements in vasomotor symptoms with standard dose estrogen. The pooled SMD is -0.64 (95% CI: -0.74 to -0.53).

Figure F-3 Vasomotor symptoms forest plot of pairwise comparisons—estrogen (low/ultralow dose) compared with placebo

Figure F-3 is a forest plot for the pairwise comparison of low/ultralow dose estrogens compared with placebo (N=53 trials) for vasomotor symptoms, Key Question 1. Seven trials had 95% confidence intervals including zero, with the remaining 46 trials showing significant improvements in vasomotor symptoms with low/ultra low dose estrogen. The pooled SMD is -0.66 (95% CI: -0.81 to -0.48).

Figure F-4 Vasomotor symptoms forest plot of pairwise comparisons—SSRIs or SNRIs compared with placebo

Figure F-4 is a forest plot for the pairwise comparison of SSRIs or SNRIs compared with placebo (N=13 trials) for vasomotor symptoms, Key Question 1. One point estimate is zero, with one additional trial having a 95% confidence interval including zero. The remaining 11 trials showed significant improvements in vasomotor symptoms with SSRIs or SNRIs. The pooled SMD is -0.35 (95% CI: -0.46 to -0.24).

Figure F-5 Vasomotor symptoms forest plot of pairwise comparisons—isoflavones compared with placebo

Figure F-B415 is a forest plot for the pairwise comparison of isoflavones compared with placebo (N=35 trials) for vasomotor symptoms, Key Question 1. Eight trials had point estimates larger than zero, and an additional 11 trials had 95% confidence intervals including zero. The remaining 16 trials showed significant improvements in vasomotor symptoms with isoflavones. The pooled SMD is -0.31 (95% CI: -0.41 to -0.22).

Figure F-6 Vasomotor symptoms forest plot of pairwise comparisons—gabapentin compared with placebo

Figure F-6 is a forest plot for the pairwise comparison of gabpentin compared with placebo (N=5 trials) for vasomotor symptoms, Key Question 1. All five trials reported significant improvements in vasomotor symptoms with gabapentin. The pooled SMD is -0.28 (95% CI: -0.38 to -0.19).

Figure F-7 Vasomotor symptoms forest plot of pairwise comparisons—black cohosh compared with placebo

Figure F-7 is a forest plot for the pairwise comparison of black cohosh compared with placebo (N=4 trials) for vasomotor symptoms, Key Question 1. Two of the four trials have 95% confidence intervals including zero. The largest trial showed significant improvement in vasomotor symptoms. The pooled SMD is -0.31 (95% CI: -0.46 to -0.15).

Figure F-8 Vasomotor symptoms forest plot of pairwise comparisons—estrogen (high dose) compared with estrogen (standard dose)

Figure F-8 is a forest plot for the pairwise comparison of high dose estrogen compared with standard dose estrogen (N=12 trials) for vasomotor symptoms, Key Question 1. All of the trials showed that high dose and standard dose estrogen were equally effective in relieving vasomotor symptoms. The pooled SMD is -0.03 (95% CUI: -0.14 to 0.09).

Figure F-9 Vasomotor symptoms forest plot of pairwise comparisons—estrogen (high dose) compared with estrogen (low/ultralow dose)

Figure F-9 is a forest plot for the pairwise comparison of high dose estrogen compared with low/ultra low dose estrogen (N=5 trials) for vasomotor symptoms, Key Question 1. All of the trials showed that high dose and low/ultra low dose estrogens were equally effective in relieving vasomotor symptoms. The pooled SMD is -0.02 (95% CUI: -0.17 to 0.13).

Figure F-10 Vasomotor symptoms forest plot of pairwise comparisons—estrogen (standard dose) compared with estrogen (low/ultralow dose)

Figure F-10 is a forest plot for the pairwise comparison of standard dose estrogen compared with low/ultra low dose estrogen (N=24 trials) for vasomotor symptoms, Key Question 1. Five trials showed standard dose estrogens significantly more effective compared with low/ultralow dose estrogens, but the remaining trials showed no difference. The pooled SMD is -0.14 (95% CUI: -0.23 to 0.05).

Figure F-11 Vasomotor symptoms forest plot of pairwise comparisons—ginseng compared with placebo

Figure F-11 is a forest plot for the pairwise comparison of ginseng compared with placebo (N=3 trials) for vasomotor symptoms, Key Question 1. Two of the three trials have 95% confidence intervals including zero. The pooled SMD is -0.17 (95% CI: -0.43 to 0.09).

Figure F-12 Plot showing consistency of closed loops with letters representing treatments^a^ a Inconsistency (95% CI excluding 0) is evident only in the treatment loop including standard dose estrogen-low/ultralow dose estrogen-black cohosh.

a: high dose estrogen; b: standard dose estrogen; c: low/ultralow dose estrogen; d: SSRI/SNRI; f: isoflavones; g: black cohosh; I: placebo.

Figure F-12 is a plot demonstrating consistency within the following closed treatment loops: high estrogen/standard estrogen/ultrlow-low estrogen; high estrogen/standard estrogen/placebo; high estrogen/ultralow-low estrogen/placebo; standard estrogen/ultralow-low estrogen/black cohosh; standard estrogen/ultralow-low estrogen/placebo; standard estrogen/black cohosh/placebo; ultralow-low estrogen/black cohosh/placebo; ultralow-low estrogen/isoflavones/placebo. The plot shows that the only inconsistency among the treatment loops was found in the loop of standard estrogen/ultralow-low estrogen/black cohosh.

Table F-1 Difference between network result and calculable pairwise effect estimates^a^

E-High
0.062 | E-Standard
-0.043 | 0.042 | E-Low/Ultralow
| | | SSRI/SNRI
| | | | Gabap/Preg
| | 0.172 | | | Isoflavone
| 0.485 | -0.363 | | | | Black Cohosh
| | | | | | | Ginseng
-0.093 | 0.013 | 0.018 | -0.021 | -0.043 | -0.005 | 0.065 | -0.020 | Placebo

a Pooled random effect estimates were used when multiple trials were available, otherwise single trial effects were used when only one trial was available. Small differences reflect network consistency.

Table F-2 Network analysis including trials (n=134) specifying vasomotor symptoms as a primary outcome and requiring symptoms; SMD and 95% credible interval

E-High
0.04 (-0.08 to 0.17) | E-Standard
-0.08 (-0.22 to 0.05) | -0.13 (-0.21 to -0.04) | E-Low/Ultralow
-0.26 (-0.44 to -0.08) | -0.30 (-0.46 to -0.14) | -0.17 (-0.32 to -0.02) | SSRI/SNRI
-0.30 (-0.54 to -0.06) | -0.34 (-0.56 to -0.12) | -0.22 (-0.43 to 0.00) | -0.04 (-0.29 to 0.21) | Gabapentin
-0.29 (-0.45 to -0.13) | -0.33 (-0.46 to -0.21) | -0.21 (-0.33 to -0.09) | -0.03 (-0.20 to 0.13) | 0.01 (-0.22 to 0.24) | Isoflavones
-0.37 (-0.62 to -0.13) | -0.41 (-0.63 to -0.20) | -0.29 (-0.51 to -0.07) | -0.12 (-0.37 to 0.13) | -0.07 (-0.37 to 0.22) | -0.08 (-0.31 to 0.15) | Black Cohosh
-0.43 (-0.77 to -0.10) | -0.48 (-0.80 to -0.16) | -0.35 (-0.66 to -0.03) | -0.18 (-0.51 to 0.16) | -0.13 (-0.51 to 0.24) | -0.14 (-0.47 to 0.18) | -0.06 (-0.44 to 0.31) | Ginseng
-0.63 (-0.75 to -0.50) | -0.67 (-0.75 to -0.59) | -0.54 (-0.61 to -0.48) | -0.37 (-0.50 to -0.24) | -0.33 (-0.54 to -0.12) | -0.33 (-0.43 to -0.23) | -0.25 (-0.46 to -0.04) | -0.19 (-0.50 to 0.12) | Placebo

Table F-3 Rankings of comparative efficacy, standard deviations, and 95% credible intervals; trials (n=134) specifying vasomotor symptoms as a primary outcome and requiring symptoms

Treatment | Mean Rank | SD | 95% CrI
E-High | 1.9 | 0.6 | (1-3)
E-Standard | 1.3 | 0.5 | (1-2)
E-Low/Ultralow | 3.0 | 0.4 | (2-4)
SSRI/SNRI | 5.0 | 1.1 | (4-7)
Gabapentin | 5.7 | 1.4 | (3-8)
Isoflavones | 5.6 | 1.1 | (4-8)
Black Cohosh | 6.6 | 1.3 | (4-8)
Ginseng | 7.1 | 1.5 | (4-9)
Placebo | 8.9 | 0.3 | (8-9)

SD: standard deviation; CrI: credible interval; E: estrogen; SSRI: selective serotonin reuptake inhibitor; SNRI: serotonin and norepinephrine reuptake inhibitor.

Table F-4 Network analysis excluding trials judged to have included women without vasomotor symptoms (n=136); SMD and 95% credible interval

E-High
0.03 (-0.10 to 0.16) | E-Standard
-0.08 (-0.22 to 0.06) | -0.11 (-0.20 to -0.02) | E-Low/Ultralow
-0.23 (-0.43 to -0.04) | -0.26 (-0.42 to -0.09) | -0.15 (-0.31 to 0.01) | SSRI/SNRI
-0.28 (-0.53 to -0.02) | -0.31 (-0.54 to -0.08) | -0.20 (-0.42 to 0.03) | -0.05 (-0.31 to 0.21) | Gabapentin
-0.27 (-0.44 to -0.10) | -0.29 (-0.43 to -0.16) | -0.18 (-0.31 to -0.06) | -0.04 (-0.21 to 0.14) | 0.01 (-0.23 to 0.25) | Isoflavones
-0.36 (-0.62 to -0.11) | -0.39 (-0.62 to -0.17) | -0.28 (-0.50 to -0.06) | -0.13 (-0.39 to 0.13) | -0.08 (-0.39 to 0.22) | -0.10 (-0.34 to 0.15) | Black Cohosh
-0.41 (-0.75 to -0.07) | -0.44 (-0.77 to -0.11) | -0.33 (-0.65 to -0.00) | -0.18 (-0.53 to 0.17) | -0.13 (-0.52 to 0.25) | -0.14 (-0.48 to 0.19) | -0.05 (-0.43 to 0.34) | Ginseng
-0.61 (-0.74 to -0.47) | -0.63 (-0.71 to -0.55) | -0.52 (-0.59 to -0.46) | -0.38 (-0.52 to -0.23) | -0.33 (-0.55 to -0.11) | -0.34 (-0.44 to -0.24) | -0.24 (-0.46 to -0.03) | -0.20 (-0.51 to 0.12) | Placebo

Table F-5 Vasomotor symptoms rankings of comparative efficacy, standard deviations, and 95% credible intervals; excluding trials judged to have included women without vasomotor symptoms

Treatment | Mean Rank | SD | 95% CrI
E-High | 1.8 | 0.7 | (1-3)
E-Standard | 1.4 | 0.5 | (1-2)
E-Low/Ultralow | 3.0 | 0.5 | (2-4)
SSRI/SNRI | 5.0 | 1.1 | (3-7)
Gabapentin | 5.7 | 1.5 | (3-8)
Isoflavones | 5.5 | 1.0 | (4-8)
Black Cohosh | 6.7 | 1.3 | (4-8)
Ginseng | 7.1 | 1.6 | (4-9)
Placebo | 8.9 | 0.3 | (8-9)

SD: standard deviation; CrI: credible interval; E: estrogen; SSRI: selective serotonin reuptake inhibitor; SNRI: serotonin and norepinephrine reuptake inhibitor.

Table F-6 Network analysis excluding black cohosh trials (n=147); SMD and 95% credible interval

E-High
0.03 (-0.10 to 0.15) | E-Standard
-0.06 (-0.19 to 0.07) | -0.08 (-0.17 to -0.00) | E-Low/Ultralow
-0.22 (-0.40 to -0.03) | -0.24 (-0.40 to -0.09) | -0.16 (-0.31 to -0.01) | SSRI/SNRI
-0.26 (-0.51 to -0.01) | -0.29 (-0.51 to -0.06) | -0.20 (-0.42 to 0.02) | -0.04 (-0.30 to 0.21) | Gabapentin
-0.28 (-0.43 to -0.12) | -0.30 (-0.42 to -0.18) | -0.22 (-0.33 to -0.10) | -0.06 (-0.23 to 0.11) | -0.02 (-0.25 to 0.22) | Isoflavones
-0.39 (-0.73 to -0.05) | -0.42 (-0.74 to -0.09) | -0.33 (-0.65 to -0.01) | -0.17 (-0.52 to 0.17) | -0.13 (-0.51 to 0.25) | -0.11 (-0.44 to 0.21) | Ginseng
-0.59 (-0.71 to -0.46) | -0.61 (-0.69 to -0.54) | -0.53 (-0.59 to -0.46) | -0.37 (-0.51 to -0.23) | -0.33 (-0.54 to -0.11) | -0.31 (-0.41 to -0.22) | -0.20 (-0.51 to 0.12) | Placebo

Table F-7 Vasomotor symptoms rankings of comparative efficacy, standard deviations, and 95% credible intervals; excluding black cohosh trials

Treatment | Mean Rank | SD | 95% CrI
E-High | 1.9 | 0.8 | (1-3)
E-Standard | 1.4 | 0.5 | (1-2)
E-Low/Ultralow | 2.9 | 0.5 | (2-4)
SSRI/SNRI | 4.7 | 0.9 | (4-7)
Gabapentin | 5.3 | 1.2 | (3-7)
Isoflavones | 5.6 | 0.9 | (4-7)
Ginseng | 6.4 | 1.3 | (4-8)
Placebo | 7.9 | 0.3 | (7-8)

SD: standard deviation; CrI: credible interval; E: estrogen; SSRI: selective serotonin reuptake inhibitor; SNRI: serotonin and norepinephrine reuptake inhibitor.

Table F-8 Network analysis including trials rated good or fair quality (n=36); SMD and 95% credible interval

E-High
0.01 (-0.24 to 0.26) | E-Standard
-0.12 (-0.39 to 0.15) | -0.13 (-0.29 to 0.03) | E-Low/Ultralow
-0.23 (-0.53 to 0.07) | -0.24 (-0.45 to -0.03) | -0.11 (-0.31 to 0.09) | SSRI/SNRI
-0.35 (-0.83 to 0.12) | -0.36 (-0.79 to 0.06) | -0.23 (-0.66 to 0.19) | -0.12 (-0.56 to 0.31) | Gabapentin
-0.44 (-0.76 to -0.13) | -0.45 (-0.69 to -0.21) | -0.32 (-0.55 to -0.09) | -0.21 (-0.46 to 0.04) | -0.09 (-0.54 to 0.35) | Isoflavones
-0.39 (-0.81 to 0.02) | -0.40 (-0.75 to -0.05) | -0.27 (-0.62 to 0.08) | -0.16 (-0.53 to 0.21) | -0.04 (-0.56 to 0.48) | 0.05 (-0.33 to 0.44) | Black Cohosh
-0.06 (-0.70 to 0.58) | -0.07 (-0.67 to 0.53) | 0.06 (-0.54 to 0.66) | 0.17 (-0.44 to 0.78) | 0.29 (-0.42 to 1.00) | 0.38 (-0.23 to 1.00) | 0.33 (-0.34 to 1.01) | Ginseng
-0.56 (-0.82 to -0.31) | -0.57 (-0.71 to -0.43) | -0.44 (-0.57 to -0.32) | -0.33 (-0.49 to -0.17) | -0.21 (-0.61 to 0.19) | -0.12 (-0.31 to 0.07) | -0.17 (-0.51 to 0.16) | -0.50 (-1.09 to 0.08) | Placebo

Table F-9 Vasomotor symptoms rankings of comparative efficacy, standard deviations, and 95% credible intervals; including trials rated good or fair quality

Treatment | Mean Rank | SD | 95% CrI
E-High | 2.3 | 1.3 | (1-5)
E-Standard | 2.0 | 0.8 | (1-4)
E-Low/Ultralow | 3.7 | 1.0 | (1-6)
SSRI/SNRI | 5.0 | 1.1 | (3-7)
Gabapetin | 6.2 | 1.9 | (2-9)
Isoflavones | 7.2 | 1.0 | (5-9)
Black Cohosh | 6.6 | 1.6 | (3-9)
Ginseng | 3.4 | 2.4 | (1-9)
Placebo | 8.6 | 0.6 | (7-9)

SD: standard deviation; CrI: credible interval; E: estrogen; SSRI: selective serotonin reuptake inhibitor; SNRI: serotonin and norepinephrine reuptake inhibitor.

Table F-10 Network analysis restricted to trials examining moderate to severe hot flush reduction (n=55); SMD and 95% credible interval

E-High
0.05 (-0.08 to 0.18) | E-Standard
-0.07 (-0.20 to 0.07) | -0.11 (-0.20 to -0.03) | E-Low/Ultralow
-0.23 (-0.41 to -0.04) | -0.27 (-0.43 to -0.12) | -0.16 (-0.31 to -0.01) | SSRI/SNRI
-0.27 (-0.52 to -0.02) | -0.32 (-0.54 to -0.09) | -0.20 (-0.42 to 0.02) | -0.04 (-0.29 to 0.21) | Gabapentin
-0.28 (-0.44 to -0.13) | -0.33 (-0.45 to -0.21) | -0.22 (-0.33 to -0.10) | -0.06 (-0.22 to 0.11) | -0.02 (-0.25 to 0.21) | Isoflavones
-0.35 (-0.60 to -0.10) | -0.40 (-0.62 to -0.18) | -0.28 (-0.50 to -0.06) | -0.12 (-0.38 to 0.13) | -0.08 (-0.38 to 0.22) | -0.06 (-0.30 to 0.17) | Black Cohosh
-0.40 (-0.74 to -0.07) | -0.45 (-0.77 to -0.13) | -0.33 (-0.65 to -0.02) | -0.18 (-0.51 to 0.16) | -0.13 (-0.51 to 0.24) | -0.12 (-0.44 to 0.21) | -0.05 (-0.43 to 0.33) | Ginseng
-0.60 (-0.72 to -0.47) | -0.64 (-0.72 to -0.57) | -0.53 (-0.59 to -0.46) | -0.37 (-0.51 to -0.23) | -0.33 (-0.54 to -0.12) | -0.31 (-0.40 to -0.22) | -0.25 (-0.46 to -0.03) | -0.19 (-0.51 to 0.12) | Placebo

Table F-11 Vasomotor symptoms rankings of comparative efficacy, standard deviations, and 95% credible intervals; trials examining moderate to severe hot flush reduction

Treatment | Mean Rank | SD | 95% CrI
E-High | 2.0 | 0.7 | (1-3)
E-Standard | 1.3 | 0.4 | (1-2)
E-Low/Ultralow | 2.9 | 0.5 | (2-4)
SSRI/SNRI | 4.9 | 1.1 | (4-7)
Gabapentin | 5.6 | 1.4 | (3-8)
Isoflavones | 5.9 | 1.0 | (4-8)
Black Cohosh | 6.6 | 1.3 | (4-8)
Ginseng | 7.1 | 1.6 | (4-9)
Placebo | 8.9 | 0.3 | (8-9)

SD: standard deviation; CrI: credible interval; E: estrogen; SSRI: selective serotonin reuptake inhibitor; SNRI: serotonin and norepinephrine reuptake inhibitor.

Table F-12 Network analysis excluding large prevention-focused trials, SMD and 95% credible interval (n=150)

E-High
0.05 (-0.07 to 0.17) | E-Standard
-0.08 (-0.20 to 0.05) | -0.12 (-0.20 to -0.04) | E-Low/Ultralow
-0.24 (-0.42 to -0.07) | -0.29 (-0.44 to -0.14) | -0.17 (-0.31 to -0.02) | SSRI/SNRI
-0.29 (-0.52 to -0.05) | -0.33 (-0.55 to -0.11) | -0.21 (-0.43 to 0.00) | -0.04 (-0.29 to 0.20) | Gabapentin
-0.30 (-0.45 to -0.15) | -0.35 (-0.47 to -0.23) | -0.23 (-0.34 to -0.12) | -0.06 (-0.22 to 0.10) | -0.02 (-0.24 to 0.21) | Isoflavones
-0.36 (-0.60 to -0.12) | -0.41 (-0.63 to -0.19) | -0.29 (-0.50 to -0.07) | -0.12 (-0.37 to 0.13) | -0.07 (-0.37 to 0.22) | -0.06 (-0.29 to 0.17) | Black Cohosh
-0.42 (-0.75 to -0.09) | -0.47 (-0.78 to -0.15) | -0.34 (-0.66 to -0.03) | -0.17 (-0.51 to 0.16) | -0.13 (-0.50 to 0.24) | -0.12 (-0.44 to 0.20) | -0.06 (-0.43 to 0.31) | Ginseng
-0.61 (-0.73 to -0.49) | -0.66 (-0.74 to -0.59) | -0.54 (-0.60 to -0.47) | -0.37 (-0.50 to -0.24) | -0.33 (-0.53 to -0.12) | -0.31 (-0.40 to -0.22) | -0.25 (-0.46 to -0.04) | -0.19 (-0.50 to 0.11) | Placebo

Table F-13 Vasomotor symptoms rankings of comparative efficacy, standard deviations, and 95% credible intervals; excluding large prevention-focused trials

Treatment | Mean Rank | SD | 95% CrI
E-High | 1.93 | 0.60 | (1-3)
E-Standard | 1.22 | 0.42 | (1-2)
E-Low/Ultralow | 2.94 | 0.41 | (2-4)
SSRI/SNRI | 4.92 | 1.05 | (4-7)
Gabapentin | 5.59 | 1.41 | (3-8)
Isoflavones | 5.86 | 1.03 | (4-8)
Black Cohosh | 6.59 | 1.31 | (4-8)
Ginseng | 7.08 | 1.52 | (4-9)
Placebo | 8.88 | 0.33 | (8-9)

SD: standard deviation; CrI: credible interval; E: estrogen; SSRI: selective serotonin reuptake inhibitor; SNRI: serotonin and norepinephrine reuptake inhibitor.