# Evidence Base for Key Question 1

Table E-1 Study characteristics for trials comparing hormone with placebo

Table E-2 Study characteristics for trials comparing antidepressant with placebo

Table E-3 Study characteristics for trials comparing other prescriptions with placebo

Table E-4 Study characteristics for trials comparing nonprescription nonhormone with placebo

Table E-5 Study characteristics for trials comparing hormone and nonprescription nonhormone with placebo

Table E-6 Study characteristics for trials comparing hormone with hormone

Table E-7 Study characteristics for trials comparing hormone with nonprescription nonhormone

Table E-8 Study characteristics for trials comparing nonprescription nonhormone with nonprescription nonhormone

Table E-9 Study characteristics for trials comparing nonprescription nonhormone with antidepressant

Table E-10 Age, BMI, and smoking status for trials comparing hormone with placebo

Table E-11 Age, BMI, and smoking status for trials comparing antidepressant with placebo

Table E-12 Age, BMI, and smoking status for trials comparing other prescriptions with placebo

Table E-13 Age, BMI, and smoking status for trials comparing nonprescription nonhormone with placebo

Table E-14 Age, BMI, and smoking status for trials comparing hormone and nonprescription nonhormone with placebo

Table E-15 Age, BMI, and smoking status for trials comparing hormone with hormone

Table E-16 Age, BMI, and smoking status for trials comparing hormone with nonprescription nonhormone

Table E-17 Age, BMI, and smoking status for trials comparing nonprescription nonhormone with nonprescription nonhormone

Table E-18 Age, BMI, and smoking status for trials comparing nonprescription nonhormone with antidepressant

Table E-19 Racial makeup for trials comparing hormone with placebo

Table E-20 Racial makeup for trials comparing antidepressant with placebo

Table E-21 Racial makeup for trials comparing other prescriptions with placebo

Table E-22 Racial makeup for trials comparing nonprescription nonhormone with placebo

Table E-23 Racial makeup for trials comparing hormone and nonprescription nonhormone with placebo

Table E-24 Racial makeup for trials comparing hormone with hormone

Table E-25 Racial makeup for trials comparing hormone with nonprescription nonhormone

Table E-26 Racial makeup for trials comparing nonprescription nonhormone with nonprescription nonhormone

Table E-27 Racial makeup for trials comparing nonprescription nonhormone with antidepressant

Table E-28 Uterus status, age since menopause, and prior HRT use for trials comparing hormone with placebo

Table E-29 Uterus status, age since menopause, and prior HRT use for trials comparing antidepressant with placebo

Table E-30 Uterus status, age since menopause, and prior HRT use for trials comparing other prescriptions with placebo

Table E-31 Uterus status, age since menopause, and prior HRT use for trials comparing nonprescription nonhormone with placebo

Table E-32 Uterus status, age since menopause, and prior HRT use for trials comparing hormone and nonprescription nonhormone with placebo

Table E-33 Uterus status, age since menopause, and prior HRT use for trials comparing hormone with hormone

Table E-34 Uterus status, age since menopause, and prior HRT use for trials comparing hormone with nonprescription nonhormone

Table E-35 Uterus status, age since menopause, and prior HRT use for trials comparing nonprescription nonhormone with nonprescription nonhormone

Table E-36 Uterus status, age since menopause, and prior HRT use for trials comparing nonprescription nonhormone with antidepressant

Table E-37 Reported outcomes for trials comparing hormone with placebo

Table E-38 Reported outcomes for trials comparing antidepressant with placebo

Table E-39 Reported outcomes for trials comparing other prescriptions with placebo

Table E-40 Reported outcomes for trials comparing nonprescription nonhormone with placebo

Table E-41 Reported outcomes for trials comparing hormone and nonprescription nonhormone with placebo

Table E-42 Reported outcomes for trials comparing hormone with hormone

Table E-43 Reported outcomes for trials comparing hormone with nonprescription nonhormone

Table E-44 Reported outcomes for trials comparing nonprescription nonhormone with nonprescription nonhormone

Table E-45 Reported outcomes for trials comparing nonprescription nonhormone with antidepressant

Table E-46 Therapies used in trials comparing hormone with placebo

Table E-47 Therapies used in trials comparing antidepressant with placebo

Table E-48 Therapies used in trials comparing other prescriptions with placebo

Table E-49 Therapies used in trials comparing nonprescription nonhormone with placebo

Table E-50 Therapies used in trials comparing hormone and nonprescription nonhormone with placebo

Table E-51 Therapies used in trials comparing hormone with hormone

Table E-52 Therapies used in trials comparing hormone with nonprescription nonhormone

Table E-53 Therapies used in trials comparing nonprescription nonhormone with nonprescription nonhormone

Table E-54 Therapies used in trials comparing nonprescription nonhormone with antidepressant

Table E-55 Study quality for trials comparing hormone with placebo

Table E-56 Study quality for trials comparing antidepressant with placebo

Table E-57 Study quality for trials comparing other prescriptions with placebo

Table E-58 Study quality for trials comparing nonprescription nonhormone with placebo

Table E-59 Study quality for trials comparing hormone and nonprescription nonhormone with placebo

Table E-60 Study quality for trials comparing hormone with hormone

Table E-61 Study quality for trials comparing hormone with nonprescription nonhormone

Table E-62 Study quality for trials comparing nonprescription nonhormone with nonprescription nonhormone

Table E-63 Study quality for trials comparing nonprescription nonhormone with antidepressant