# Estrogen Dosing Categories

Table D-1 Estrogen dosing categories

Mode of administration | Dose Category | 17B-estradiol | Conjugated equine estrogen | Estradiol valerate | Estrone sulphate (estropipate or estrone piperazine) | Esterified estrogen | Ethinyl estradiol | Estradiol acetate
Oral | Ultra low | 0.5mg | 0.15mg 0.3mg | -- | 0.3mg | -- | -- | --
Oral | Low | 1.0mg | 0.4mg | 0.5mg | 0.625mg | 0.3mg | <0.010mg | --
Oral | Standard | 1.5mg 2mg | 0.625mg | 1mg | 1.25mg 1.5mg | 0.625mg | 0.010mg | --
Oral | High | 4mg | 1.25mg | 2mg | 2.5mg | 1.25mg | >0.010mg | --
Transdermal Patch | Ultra low | 0.025mg | -- | -- | -- | -- | -- | --
Transdermal Patch | Low | 0.0375mg | -- | -- | -- | -- | -- | --
Transdermal Patch | Standard | 0.05mg | -- | -- | -- | -- | -- | --
Transdermal Patch | High | 0.075mg 0.1mg | -- | -- | -- | -- | -- | --
Vaginal Cream | Ultra low | | -- | -- | -- | -- | -- | --
Vaginal Cream | Low | 0.1 mg | -- | -- | -- | -- | -- | --
Vaginal Cream | Standard | | 0.625 mg | -- | -- | 1.0 mg | -- | --
Vaginal Cream | High | -- | -- | -- | -- | -- | -- | --
Vaginal Ring | Ultra low | -- | -- | -- | -- | -- | -- | --
Vaginal Ring | Low | 0.0075mg | -- | -- | -- | -- | -- | --
Vaginal Ring | Standard | -- | -- | -- | -- | -- | -- | --
Vaginal Ring | High | -- | -- | -- | -- | -- | -- | 0.05 mg 0.10 mg
Topical (cream, spray, gel) | Ultra low | 0.01% (gel) 0.03% (gel) | -- | -- | -- | -- | -- | --
Topical (cream, spray, gel) | Low | 1.5 mg (spray) 0.04% (gel) 0.06% (gel) 0.10% (gel) | -- | -- | -- | -- | -- | --
Topical (cream, spray, gel) | Standard | 0.05 mg (cream) | -- | -- | -- | -- | -- | --
Topical (cream, spray, gel) | High | -- | -- | -- | -- | -- | -- | --
Vaginal (pessary/suppository, tablet) | Ultra low | -- | -- | -- | -- | -- | -- | --
Vaginal (pessary/suppository, tablet) | Low | 0.01 mg 0.0258 mg | -- | -- | -- | -- | -- | --
Vaginal (pessary/suppository, tablet) | Standard | -- | -- | -- | -- | -- | -- | --
Vaginal (pessary/suppository, tablet) | High | -- | -- | -- | -- | -- | -- | --