# Abstraction Forms

Table C-1 Key Question 1, Form 1: study characteristics

Table C-2 Key Question 1, Form 2: study arm characteristics

Table C-3 Key Question 1, Form 3: vasomotor outcomes (estimating up to 3 different vasomotor outcomes reported in a single study)

Table C-4 Key Question 1, Form 4: sleep disturbance outcomes (estimating up to 2 different sleep outcomes reported in a single study)

Table C-5 Key Question 1, Form 5: psychological outcomes (estimating up to 3 different psychological outcomes reported in a single study)

Table C-6 Key Question 1, Form 6: urogenital atrophy (estimating up to 2 QOL measures reported in a single study)

Table C-7 Key Question 1, Form 7: quality of life outcomes (estimating up to 2 QOL measures reported in a single study)

Table C-8 Key Question 1, Form 8: sexual function outcomes (estimating up to 2 different sexual outcomes reported in a single study)

Table C-9 Key Question 1, Form 9: study quality