# List of Excluded Studies

Abbreviations
DES: date earlier than systematic review
DUP: duplicate patient population or duplicate article
NCT: not clinical trial, MA, or SR
NOP: number of patients (too few)
NRC: not relevant comparator
NRD: not relevant design
NRF: not relevant followup
NRO: not relevant outcome
NRP: not relevant population
NRQ: not relevant question
PTU: prior to USPSTF report

Adami H. O., Persson I., Hoover R., Schairer C., Bergkvist L. Risk of cancer in women receiving hormone replacement therapy. Int J Cancer. 1989;44(5):833-9. DES. [pmid: 2583865].
Aidelsburger P., Schauer S., Grabein K., Wasem J. Alternative methods for the treatment of post-menopausal troubles. GMS Health Technol Assess. 2012;8. Doc03. NRD.
AinMelk Y. Comparison of two continuous combined estrogen progestogen regimens in postmenopausal women: a randomized trial. Fertil Steril. 1996;66(6):962-8. NRO. [pmid: 8941062].
Akhavan S., Zandvakili F., Arab M., Karimi H., Gharibi F. Comparison of the therapeutic effects of fluoxetine, citalopram, estrogen and progesterone and placebo in the treatment of hot flushes in perimenopausal women. Scientific Journal of Kurdistan University of Medical Sciences. 2011;16(3). NCT.
Al-Azzawi F., Buckler H. M. Comparison of a novel vaginal ring delivering estradiol acetate versus oral estradiol for relief of vasomotor menopausal symptoms. Climacteric. 2003;6(2):118-27. DUP. [pmid: 12841882].
Al-Azzawi F., Wahab M., Thompson J., Whitehead M., Thompson W. Acceptability and patterns of uterine bleeding in sequential trimegestone-based hormone replacement therapy: a dose-ranging study. Hum Reprod. 1999;14(3):636-41. NRO. [pmid: 10221688].
Albertazzi P., Steel S. A., Bottazzi M. Effect of pure genistein on bone markers and hot flushes. Climacteric. 2005;8(4):371-9. NRF. [pmid: 16390772].
Alexander I. M., Moore A. Treating vasomotor symptoms of menopause: the nurse practitioner's perspective. J Am Acad Nurse Pract. 2007;19(3):152-63. NRD. [pmid: 17341283].
Alexander J. L., Kotz K., Dennerstein L., Kutner S. J., Wallen K., Notelovitz M. The effects of postmenopausal hormone therapies on female sexual functioning: a review of double-blind, randomized controlled trials. Menopause. 2004;11(6 Pt 2):749-65. NRD. [pmid: 15543027].
Alexander J. L., Dennerstein L., Burger H., Graziottin A. Testosterone and libido in surgically and naturally menopausal women. Women's Health. 2006;2(3):459-477. NRD.
Alexander K. P., Newby L. K., Hellkamp A. S., Harrington R. A., Peterson E. D., Kopecky S., Langer A., O'Gara P., O'Connor C. M., Daly R. N., Califf R. M., Khan S., Fuster V. Initiation of hormone replacement therapy after acute myocardial infarction is associated with more cardiac events during follow-up. J Am Coll Cardiol. 2001;38(1):1-7. DES. [pmid: 11451256].
Alexandersen P., Tanko L. B., Bagger Y. Z., Qin G., Christiansen C. The long-term impact of 2-3 years of hormone replacement therapy on cardiovascular mortality and atherosclerosis in healthy women. Climacteric. 2006;9(2):108-18. DES. [pmid: 16698657].
Allison M. A., Manson J. E. Age, hormone therapy use, coronary heart disease, and mortality. Menopause. 2011;18(3):243-245. NRD. [pmid: 21301373].
Altman D. G. A meta-analysis of hormone replacement therapy for fracture prevention. JAMA. 2001;286(17):2096-7. NCT. [pmid: 11694148].
van Anders S. M., Chernick A. B., Chernick B. A., Hampson E., Fisher W. A. Preliminary clinical experience with androgen administration for pre- and postmenopausal women with hypoactive sexual desire. J Sex Marital Ther. 2005;31(3):173-85. NOP. [pmid: 16020137].
Anderson G. L., Judd H. L., Kaunitz A. M., Barad D. H., Beresford S. A., Pettinger M., Liu J., McNeeley S. G., Lopez A. M. Effects of estrogen plus progestin on gynecologic cancers and associated diagnostic procedures: the Women's Health Initiative randomized trial. JAMA. 2003;290(13):1739-48. DES. [pmid: 14519708].
Anderson G. L., Autier P., Beral V., Bosland M. C., Fernandez E., Haslam S. Z., Kaufman D. G., La Vecchia C., Molinolo A. A., Newcomb P. A., Parl F. F., Peto J., Rosano G., Roy D., Stanczyk F. Z., Thomas D. B., Vatten L., Junghans T., Olin S., Shapiro S., Stafford R. S., Jameson C. W., Meyer J. U., Baan R., Berthiller J., Cogliano V. J., Dresler C., El Ghissassi F., Franceschi S., Goncalves M. A. G., Grosse Y., Guha N., Marron M., Mitchell J., Napalkov N., Secretan B., Straif K., Ullrich A., Egraz S., Kajo B., Lezere M., Lorenzen-Augros H. Combined estrogen-progestogen menopausal therapy. 2007;91:205-372. NCT.
Anderson G. L., Chlebowski R. T., Rossouw J. E., Rodabough R. J., McTiernan A., Margolis K. L., Aggerwal A., David Curb J., Hendrix S. L., Allan Hubbell F., Khandekar J., Lane D. S., Lasser N., Lopez A. M., Potter J., Ritenbaugh C. Prior hormone therapy and breast cancer risk in the Women's Health Initiative randomized trial of estrogen plus progestin. Maturitas. 2006;55(2):103-15. DES. [pmid: 16815651].
D'Anna R., Cannata M. L., Atteritano M., Cancellieri F., Corrado F., Baviera G., Triolo O., Antico F., Gaudio A., Frisina N., Bitto A., Polito F., Minutoli L., Altavilla D., Marini H., Squadrito F. Effects of the phytoestrogen genistein on hot flushes, endometrium, and vaginal epithelium in postmenopausal women: a 1-year randomized, double-blind, placebo-controlled study. Menopause. 2007;14(4):648-55. DUP. [pmid: 17251874].
Antunes C. M., Strolley P. D., Rosenshein N. B., Davies J. L., Tonascia J. A., Brown C., Burnett L., Rutledge A., Pokempner M., Garcia R. Endometrial cancer and estrogen use. Report of a large case-control study. N Engl J Med. 1979;300(1):9-13. DES. [pmid: 213722].
Arana A., Varas C., Gonzalez-Perez A., Gutierrez L., Bjerrum L., Garcia Rodriguez L. A. Hormone therapy and cerebrovascular events: a population-based nested case-control study. Menopause. 2006;13(5):730-6. DES. [pmid: 16946686].
Archer D. F. Drospirenone and estradiol: a new option for the postmenopausal woman. Climacteric. Suppl 1. 2007;10:3-10. NRD. [pmid: 17364592].
Archer D. F. The effect of the duration of progestin use on the occurrence of endometrial cancer in postmenopausal women. Menopause. 2001;8(4):245-51. NCT. [pmid: 11449081].
Archer D. F., Sturdee D. W., Baber R., De Villiers J. T., Pines A., Freedman R. R., Gompel A., Hickey M., Hunter M. S., Lobo R. A., Lumsden M. A., MacLennan A. H., Maki P., Palacios S., Shah D., Villaseca P., Warren M. Menopausal hot flushes and night sweats: Where are we now?. Climacteric. 2011;14(5):515-528. NRD. [pmid: 21848495].
Archer D. F., Sturdee D. W., Baber R., de Villiers T. J., Pines A., Freedman R. R., Gompel A., Hickey M., Hunter M. S., Lobo R. A., Lumsden M. A., MacLennan A. H., Maki P., Palacios S., Shah D., Villaseca P., Warren M. Menopausal hot flushes and night sweats: where are we now?. Climacteric. 2011;14(5):515-28. NRQ. [pmid: 21848495].
Archer D. F., Thorneycroft I. H., Foegh M., Hanes V., Glant M. D., Bitterman P., Kempson R. L. Long-term safety of drospirenone-estradiol for hormone therapy: a randomized, double-blind, multicenter trial. Menopause. 2005;12(6):716-27. NRO. [pmid: 16278615].
Archer D. F., Shifren J. L., Cheng R. F. J., Bao W., Guico-Pabia C. J. Tolerability of desvenlafaxine 100 mg in women with vasomotor symptoms (VMS) associated with menopause: A pooled analysis of 5 trials. Fertility and Sterility. 2011;96(3):S4-S5. NRD.
Archer D. F., Furst K., Tipping D., Dain M. P., Vandepol C. A randomized comparison of continuous combined transdermal delivery of estradiol-norethindrone acetate and estradiol alone for menopause. CombiPatch Study Group. Obstet Gynecol. 1999;94(4):498-503. NRC. [pmid: 10511348].
Archer D. F., Fischer L. A., Rich D., Schade G. H., Schwartz S., Wittcoff H., Clark C. S. Sr, Maloney K., Smith F. O. Estrace(registered trademark) vs Premarin(registered trademark) for treatment of menopausal symptoms: Dosage comparison study. Advances in Therapy. 1992;9(1):21-31. NOP.
Ascott-Evans B. H., Sonnendecker E. W. W., de Villiers T. Hormone therapy in postmenopausal osteoporosis: 2008. Journal of Endocrinology, Metabolism and Diabetes of South Africa. 2008;13(1):8-12. DES.
Aso T., Uchiyama S., Matsumura Y., Taguchi M., Nozaki M., Takamatsu K., Ishizuka B., Kubota T., Mizunuma H., Ohta H. A natural S-equol supplement alleviates hot flushes and other menopausal symptoms in equol nonproducing postmenopausal Japanese women. J Womens Health (Larchmt). 2012;21(1):92-100. DUP. [pmid: 21992596].
Atsma F., Bartelink M. L., Grobbee D. E., van der Schouw Y. T. Postmenopausal status and early menopause as independent risk factors for cardiovascular disease: a meta-analysis. Menopause. 2006;13(2):265-79. NRO. [pmid: 16645540].
Atteritano M., Mazzaferro S., Bitto A., Cannata M. L., D'Anna R., Squadrito F., Macri I., Frisina A., Frisina N., Bagnato G. Genistein effects on quality of life and depression symptoms in osteopenic postmenopausal women: a 2-year randomized, double-blind, controlled study. Osteoporos Int. 2013. NRP.
Au G. K. Evaluation of the benefits and risks of hormone replacement therapy. Hong Kong Med J. 2000;6(4):381-9. PTU. [pmid: 11177160].
Auerbach L., Rakus J., Bauer C., Gerner C., Ullmann R., Wimmer H., Huber J. Pomegranate seed oil in women with menopausal symptoms: a prospective randomized, placebo-controlled, double-blinded trial. Menopause. 2012;19(4):426-32. DUP. [pmid: 22240636].
Aylward M., Holly F., Parker R. J. An evaluation of clinical response to piperazine oestrone sulphate ('Harmogen') in menopause patients. Curr Med Res Opin. 1974;2(7):417-23. NOP. [pmid: 4375554].
al-Azzawi F., Wahab M., Thompson J., Pornel B., Hirvonen E., Ylikorkala O., van der Mooren M. J., Dillon J., Magaril C. Acceptability and patterns of endometrial bleeding in estradiol-based HRT regimens: a comparative study of cyclical sequential combinations of trimegestone or norethisterone acetate. Climacteric. 2001;4(4):343-54. NRC. [pmid: 11770191].
Bachmann G. A. Menopausal vasomotor symptoms: a review of causes, effects and evidence-based treatment options. J Reprod Med. 2005;50(3):155-65. NRD. [pmid: 15841927].
Bachmann G. A., Komi J. O. Ospemifene effectively treats vulvovaginal atrophy in postmenopausal women: results from a pivotal phase 3 study. Menopause. 2010;17(3):480-6. NRO. [pmid: 20032798].
Bagger Y. Z., Tanko L. B., Alexandersen P., Hansen H. B., Mollgaard A., Ravn P., Qvist P., Kanis J. A., Christiansen C. Two to three years of hormone replacement treatment in healthy women have long-term preventive effects on bone mass and osteoporotic fractures: the PERF study. Bone. 2004;34(4):728-35. DES. [pmid: 15050905].
Bai W., Henneicke-von Zepelin H. H., Wang S., Zheng S., Liu J., Zhang Z., Geng L., Hu L., Jiao C., Liske E. Efficacy and tolerability of a medicinal product containing an isopropanolic black cohosh extract in Chinese women with menopausal symptoms: a randomized, double blind, parallel-controlled study versus tibolone. Maturitas. 2007;58(1):31-41. NRC. [pmid: 17587516].
Bakken K., Fournier A., Lund E., Waaseth M., Dumeaux V., Clavel-Chapelon F., Fabre A., Hemon B., Rinaldi S., Chajes V., Slimani N., Allen N. E., Reeves G. K., Bingham S., Khaw K. T., Olsen A., Tjonneland A., Rodriguez L., Sanchez M. J., Etxezarreta P. A., Ardanaz E., Tormo M. J., Peeters P. H., van Gils C. H., Steffen A., Schulz M., Chang-Claude J., Kaaks R., Tumino R., Gallo V., Norat T., Riboli E., Panico S., Masala G., Gonzalez C. A., Berrino F. Menopausal hormone therapy and breast cancer risk: impact of different treatments. The European Prospective Investigation into Cancer and Nutrition. Int J Cancer. 2011;128(1):144-56. DES. [pmid: 20232395].
Balk E., Chung M., Chew P., Ip S., Raman G., Kupelnick B., Tatsioni A., Sun Y., Wolk B., DeVine D., Lau J. Effects of soy on health outcomes. Evid Rep Technol Assess (Summ). 2005;(126):1-8. NRD.
Barad D., Kooperberg C., Wactawski-Wende J., Liu J., Hendrix S. L., Watts N. B. Prior oral contraception and postmenopausal fracture: a Women's Health Initiative observational cohort study. Fertil Steril. 2005;84(2):374-83. DES. [pmid: 16084878].
Barlow D. H. Menopause and HRT--the state of the art in Europe. Maturitas. 2005;51(1):40-7. NCT. [pmid: 15883108].
Barlow D. H. HRT and the risk of deep vein thrombosis. Int J Gynaecol Obstet. Suppl 1. 1997;59:S29-33. NCT. [pmid: 9386213].
Barnabei V. M., Cochrane B. B., Aragaki A. K., Nygaard I., Williams R. S., McGovern P. G., Young R. L., Wells E. C., O'Sullivan M. J., Chen B., Schenken R., Johnson S. R. Menopausal symptoms and treatment-related effects of estrogen and progestin in the Women's Health Initiative. Obstet Gynecol. 2005;105(5 Pt 1):1063-73. DUP. [pmid: 15863546].
Barnabei V. M., Grady D., Stovall D. W., Cauley J. A., Lin F., Stuenkel C. A., Stefanick M. L., Pickar J. H. Menopausal symptoms in older women and the effects of treatment with hormone therapy. Obstet Gynecol. 2002;100(6):1209-18. NRP. [pmid: 12468165].
Barrett-Connor E. The menopause, hormone replacement, and cardiovascular disease: the epidemiologic evidence. Maturitas. 1996;23(2):227-34. NCT. [pmid: 8735360].
Barrett-Connor E., Grady D. Hormone replacement therapy, heart disease, and other considerations. Annu Rev Public Health. 1998;19:55-72. NCT. [pmid: 9611612].
Barrett-Connor E., Young R., Notelovitz M., Sullivan J., Wiita B., Yang H. M., Nolan J. A two-year, double-blind comparison of estrogen-androgen and conjugated estrogens in surgically menopausal women. Effects on bone mineral density, symptoms and lipid profiles. J Reprod Med. 1999;44(12):1012-20. NRO. [pmid: 10649811].
Barton D., Loprinzi C. L. Making sense of the evidence regarding nonhormonal treatments for hot flashes. Clin J Oncol Nurs. 2004;8(1):39-42. NCT. [pmid: 14983762].
Barzi A., Lenz A. M., Labonte M. J., Lenz H. J. Molecular pathways: Estrogen pathway in colorectal cancer. Clin Cancer Res. 2013;19:5842-8. NCT. [pmid: 23965904].
Basaria S., Dobs A. S. Clinical review: Controversies regarding transdermal androgen therapy in postmenopausal women. J Clin Endocrinol Metab. 2006;91(12):4743-52. NRD. [pmid: 16984993].
Basch E., Bent S., Collins J., Dacey C., Hammerness P., Harrison M., Smith M., Szapary P., Ulbricht C., Vora M., Weissner W. Flax and flaxseed oil (Linum usitatissimum): a review by the Natural Standard Research Collaboration. J Soc Integr Oncol. 2007;5(3):92-105. NCT. [pmid: 17761128].
Basson R. Androgen replacement for women. Can Fam Physician. 1999;45:2100-7. NCT. [pmid: 10509222].
Bath P. M., Gray L. J. Association between hormone replacement therapy and subsequent stroke: a meta-analysis. BMJ. 2005;330(7487):342. PTU. [pmid: 15640250].
Bea J. W., Zhao Q., Cauley J. A., LaCroix A. Z., Bassford T., Lewis C. E., Jackson R. D., Tylavsky F. A., Chen Z. Effect of hormone therapy on lean body mass, falls, and fractures: 6-year results from the Women's Health Initiative hormone trials. Menopause. 2011;18(1):44-52. DES. [pmid: 20689466].
Beard C. M., Kottke T. E., Annegers J. F., Ballard D. J. The Rochester Coronary Heart Disease Project: effect of cigarette smoking, hypertension, diabetes, and steroidal estrogen use on coronary heart disease among 40- to 59-year-old women, 1960 through 1982. Mayo Clin Proc. 1989;64(12):1471-80. DES. [pmid: 2557493].
Becker S., Kaaks R. Exogenous and endogenous hormones, mammographic density and breast cancer risk: can mammographic density be considered an intermediate marker of risk?. Recent Results Cancer Res. 2009;181:135-57. NRO. [pmid: 19213565].
Beckermann M. J. Estrogen-progestin hormone replacement therapy: Evaluation of epidemiological studies. HeartDrug. 2001;1(4):215-224. NRO.
Bedell S., Nachtigall M., Naftolin F. The pros and cons of plant estrogens for menopause. Journal of Steroid Biochemistry and Molecular Biology. 2014;139:225-236. NCT. [pmid: 23270754].
Belisle S., Blake J., Basson R., Desindes S., Graves G., Grigoriadis S., Johnston S., Lalonde A., Mills C., Nash L., Reid R., Rowe T., Senikas V., Turek M. Canadian Consensus Conference on menopause, 2006 update. J Obstet Gynaecol Can. 2006;28(2 Suppl 1):S7-94. NRD. [pmid: 16626522].
Beral V., Banks E., Reeves G. Evidence from randomised trials on the long-term effects of hormone replacement therapy. Lancet. 2002;360(9337):942-4. PTU. [pmid: 12354487].
Beresford S. A., Weiss N. S., Voigt L. F., McKnight B. Risk of endometrial cancer in relation to use of oestrogen combined with cyclic progestagen therapy in postmenopausal women. Lancet. 1997;349(9050):458-61. DES. [pmid: 9040575].
Bergkvist L., Adami H. O., Persson I., Hoover R., Schairer C. The risk of breast cancer after estrogen and estrogen-progestin replacement. N Engl J Med. 1989;321(5):293-7. DES. [pmid: 2546079].
Bergkvist L., Persson I., Adami H. O., Schairer C. Risk factors for breast and endometrial cancer in a cohort of women treated with menopausal oestrogens. Int J Epidemiol. 1988;17(4):732-7. DES. [pmid: 3225079].
Bernstein L. The risk of breast, endometrial and ovarian cancer in users of hormonal preparations. Basic Clin Pharmacol Toxicol. 2006;98(3):288-96. PTU. [pmid: 16611204].
Bhavnani B. R., Strickler R. C. Menopausal hormone therapy. J Obstet Gynaecol Can. 2005;27(2):137-62. NCT. [pmid: 15937590].
Bibbins-Domingo K., Lin F., Vittinghoff E., Barrett-Connor E., Hulley S. B., Grady D., Shlipak M. G. Predictors of heart failure among women with coronary disease. Circulation. 2004;110(11):1424-30. DES. [pmid: 15353499].
Biglia N., Gadducci A., Ponzone R., Roagna R., Sismondi P. Hormone replacement therapy in cancer survivors. Maturitas. 2004;48(4):333-46. NRP. [pmid: 15283925].
Biglia N., Sgro L., Defabiani E., De Rosa G., Ponzone R., Marenco D., Sismondi P. The influence of hormone replacement therapy on the pathology of breast cancer. Eur J Surg Oncol. 2005;31(5):467-72. DES. [pmid: 15922881].
Biglia N., Sgandurra P., Peano E., Marenco D., Moggio G., Bounous V., Tomasi Cont N., Ponzone R., Sismondi P. Non-hormonal treatment of hot flushes in breast cancer survivors: gabapentin vs. vitamin E. Climacteric. 2009;12(4):310-8. NRP. [pmid: 19415540].
Billeci A. M., Paciaroni M., Caso V., Agnelli G. Hormone replacement therapy and stroke. Curr Vasc Pharmacol. 2008;6(2):112-23. NCT. [pmid: 18393913].
Billeci A. M. R., Caso V., Paciaroni M., Palmerini F., Agnelli G. Hormone-replacement therapy, dementia and stroke. Women's Health. 2007;3(6):699-710. DES.
Bitzer J., Kenemans P., Mueck A. O. Breast cancer risk in postmenopausal women using testosterone in combination with hormone replacement therapy. Maturitas. 2008;59(3):209-18. PTU. [pmid: 18343056].
Bjarnason K., Cerin A., Lindgren R., Weber T. Adverse endometrial effects during long cycle hormone replacement therapy. Scandinavian Long Cycle Study Group. Maturitas. 1999;32(3):161-70. DES. [pmid: 10515673].
Bjorn I., Bixo M., Nojd K. S., Nyberg S., Backstrom T. Negative mood changes during hormone replacement therapy: a comparison between two progestogens. Am J Obstet Gynecol. 2000;183(6):1419-26. NOP. [pmid: 11120505].
Blank R. D., Bockman R. S. A review of clinical trials of therapies for osteoporosis using fracture as an end point. J Clin Densitom. 1999;2(4):435-52. PTU. [pmid: 10677797].
Body J. J., Bergmann P., Boonen S., Boutsen Y., Devogelaer J. P., Goemaere S., Kaufman J. M., Rozenberg S., Reginster J. Y. Evidence-based guidelines for the pharmacological treatment of postmenopausal osteoporosis: a consensus document by the Belgian Bone Club. Osteoporos Int. 2010;21(10):1657-80. NRD. [pmid: 20480148].
Bolanos R., Del A. Castillo and J. Francia. Soy isoflavones versus placebo in the treatment of climacteric vasomotor symptoms: systematic review and meta-analysis. Menopause. 2010;17(3):660-6. NRD. [pmid: 20464785].
Bolanos-Diaz R., Zavala-Gonzales J. C., Mezones-Holguin E., Francia-Romero J. Soy extracts versus hormone therapy for reduction of menopausal hot flushes: Indirect comparison. Menopause. 2011;18(7):825-829. NRD. [pmid: 21358349].
Bolour S., Braunstein G. Testosterone therapy in women: a review. Int J Impot Res. 2005;17(5):399-408. NCT. [pmid: 15889125].
Boothby L. A., Doering P. L., Kipersztok S. Bioidentical hormone therapy: a review. Menopause. 2004;11(3):356-67. NRD. [pmid: 15167316].
Bora K. S., Sharma A. Phytochemical and pharmacological potential of Medicago sativa: A review. Pharmaceutical Biology. 2011;49(2):211-220. NRQ. [pmid: 20969516].
Borgquist S., Anagnostaki L., Jirstrom K., Landberg G., Manjer J. Breast tumours following combined hormone replacement therapy express favourable prognostic factors. Int J Cancer. 2007;120(10):2202-7. DES. [pmid: 17278089].
Borrelli F., Ernst E. Black cohosh (Cimicifuga racemosa) for menopausal symptoms: a systematic review of its efficacy. Pharmacol Res. 2008;58(1):8-14. NRD. [pmid: 18585461].
Borrelli F., Ernst E. Alternative and complementary therapies for the menopause. Maturitas. 2010;66(4):333-43. NRD. [pmid: 20580501].
Borrelli F., Ernst E. Cimicifuga racemosa: a systematic review of its clinical efficacy. Eur J Clin Pharmacol. 2002;58(4):235-41. NRD. [pmid: 12136368].
Bottiglione F., Volpe A., Esposito G., Aloysio D. D. Transvaginal estriol administration in postmenopausal women: a double blind comparative study of two different doses. Maturitas. 1995;22(3):227-32. NRF. [pmid: 8746880].
Bouchard P., Panay N., de Villiers T. J., Vincendon P., Bao W., Cheng R. J., Constantine G. Randomized placebo- and active-controlled study of desvenlafaxine for menopausal vasomotor symptoms. Climacteric. 2012;15(1):12-20. DUP. [pmid: 22066790].
Boucher B. A., Cotterchio M., Anderson L. N., Kreiger N., Kirsh V. A., Thompson L. U. Use of isoflavone supplements is associated with reduced postmenopausal breast cancer risk. International Journal of Cancer. 2013;132(6):1439-1450. NRP.
Boyd N. F., Melnichouk O., Martin L. J., Hislop G., Chiarelli A. M., Yaffe M. J., Minkin S. Mammographic density, response to hormones, and breast cancer risk. J Clin Oncol. 2011;29(22):2985-92. DES. [pmid: 21709206].
Brandao C. M., Lima M. G., Silva A. L., Silva G. D., Guerra A. A. Jr., Acurcio Fde A. Treatment of postmenopausal osteoporosis in women: a systematic review. Cad Saude Publica. Suppl 4. 2008;24:s592-606. NRO. [pmid: 18797733].
Braunstein G. D. Safety of testosterone treatment in postmenopausal women. Fertil Steril. 2007;88(1):1-17. NRQ. [pmid: 17493618].
Braunstein G. D. Management of female sexual dysfunction in postmenopausal women by testosterone administration: safety issues and controversies. J Sex Med. 2007;4(4 Pt 1):859-66. NRQ. [pmid: 17627735].
Breast cancer and hormone replacement therapy: collaborative reanalysis of data from 51 epidemiological studies of 52,705 women with breast cancer and 108,411 women without breast cancer. Collaborative Group on Hormonal Factors in Breast Cancer. Lancet. 1997;350(9084):1047-59. PTU. [pmid: 10213546].
Brincat M., Magos A., Studd J. W., Cardozo L. D., O'Dowd T., Wardle P. J., Cooper D. Subcutaneous hormone implants for the control of climacteric symptoms. A prospective study. Lancet. 1984;1(8367):16-8. NOP. [pmid: 6140343].
Brinton L. A., Felix A. S. Menopausal hormone therapy and risk of endometrial cancer. J Steroid Biochem Mol Biol. 2013. NCT.
Brinton L. A., Schairer C. Estrogen replacement therapy and breast cancer risk. Epidemiol Rev. 1993;15(1):66-79. PTU. [pmid: 8405213].
Brinton L. A., Hoover R. N. Estrogen replacement therapy and endometrial cancer risk: unresolved issues. The Endometrial Cancer Collaborative Group. Obstet Gynecol. 1993;81(2):265-71. DES. [pmid: 8380913].
Brinton L. A., Brogan D. R., Coates R. J., Swanson C. A., Potischman N., Stanford J. L. Breast cancer risk among women under 55 years of age by joint effects of usage of oral contraceptives and hormone replacement therapy. Menopause. 1998;5(3):145-51. DES. [pmid: 9774759].
Brinton L. A., Richesson D., Leitzmann M. F., Gierach G. L., Schatzkin A., Mouw T., Hollenbeck A. R., Lacey J. V. Jr. Menopausal hormone therapy and breast cancer risk in the NIH-AARP Diet and Health Study Cohort. Cancer Epidemiol Biomarkers Prev. 2008;17(11):3150-60. DES. [pmid: 18990757].
Brinton L. A., Hoover R., Fraumeni J. F. Jr. Menopausal oestrogens and breast cancer risk: an expanded case-control study. Br J Cancer. 1986;54(5):825-32. DES. [pmid: 3801275].
Brinton L. A., Hoover R. N., Szklo M., Fraumeni J. F. Jr. Menopausal estrogen use and risk of breast cancer. Cancer. 1981;47(10):2517-22. DES. [pmid: 6268273].
Bromley S. E., de Vries C. S., Thomas D., Farmer R. D. Hormone replacement therapy and risk of acute myocardial infarction : a review of the literature. Drug Saf. 2005;28(6):473-93. PTU. [pmid: 15924502].
Brown J. N., Wright B. R. Use of gabapentin in patients experiencing hot flashes. Pharmacotherapy. 2009;29(1):74-81. NRD. [pmid: 19113798].
Brown S. Soy isoflavones fail to prevent bone loss or menopausal symptoms. Menopause International. 2011;17(4):117. NCT.
Bruhat M., Rudolf K., Vaheri R., Kainulainen P., Timonen U., Viitanen A. Effective bleeding control and symptom relief by lower dose regimens of continuous combined hormone replacement therapy: a randomized comparative dose-ranging study. Maturitas. 2001;40(3):259-71. NRC. [pmid: 11731187].
Brunner R. L., Aragaki A., Barnabei V., Cochrane B. B., Gass M., Hendrix S., Lane D., Ockene J., Woods N. F., Yasmeen S., Stefanick M. Menopausal symptom experience before and after stopping estrogen therapy in the Women's Health Initiative randomized, placebo-controlled trial. Menopause. 2010;17(5):946-54. NRQ. [pmid: 20505547].
Buck K., Zaineddin A. K., Vrieling A., Linseisen J., Chang-Claude J. Meta-analyses of lignans and enterolignans in relation to breast cancer risk. Am J Clin Nutr. 2010;92(1):141-53. NRP. [pmid: 20463043].
Buring J. E., Hennekens C. H., Lipnick R. J., Willett W., Stampfer M. J., Rosner B., Peto R., Speizer F. E. A prospective cohort study of postmenopausal hormone use and risk of breast cancer in US women. Am J Epidemiol. 1987;125(6):939-47. DES. [pmid: 3578252].
Bushnell C. Hormone therapy and stroke: Is it all about timing?. Current Treatment Options in Cardiovascular Medicine. 2009;11(3):241-250. NCT. [pmid: 19433019].
Buyon J. P., Petri M. A., Kim M. Y., Kalunian K. C., Grossman J., Hahn B. H., Merrill J. T., Sammaritano L., Lockshin M., Alarcon G. S., Manzi S., Belmont H. M., Askanase A. D., Sigler L., Dooley M. A., Von Feldt J., McCune W. J., Friedman A., Wachs J., Cronin M., Hearth-Holmes M., Tan M., Licciardi F. The effect of combined estrogen and progesterone hormone replacement therapy on disease activity in systemic lupus erythematosus: a randomized trial. Ann Intern Med. 2005;142(12 Pt 1):953-62. DES. [pmid: 15968009].
Calle E. E., Feigelson H. S., Hildebrand J. S., Teras L. R., Thun M. J., Rodriguez C. Postmenopausal hormone use and breast cancer associations differ by hormone regimen and histologic subtype. Cancer. 2009;115(5):936-45. DES. [pmid: 19156895].
Calvocoressi L., Stowe M. H., Carter D., Claus E. B. Postmenopausal hormone therapy and ductal carcinoma in situ: A population-based case-control study. Cancer Epidemiology. 2012. DES.
Calvocoressi L., Stowe M. H., Carter D., Claus E. B. Postmenopausal hormone therapy and ductal carcinoma in situ: a population-based case-control study. Cancer Epidemiol. 2012;36(2):161-8. DES. [pmid: 22317899].
Cameron S. T., Glasier A. F., Gebbie A., Dewart H., Baird D. T. Comparison of a transdermal continuous combined and an interrupted progestogen HRT. Maturitas. 2006;53(1):19-26. NRO. [pmid: 16325020].
Campagnoli C., Abba C., Ambroggio S., Peris C., Perona M., Sanseverino P. Polyunsaturated fatty acids (PUFAs) might reduce hot flushes: an indication from two controlled trials on soy isoflavones alone and with a PUFA supplement. Maturitas. 2005;51(2):127-34. NOP. [pmid: 15917152].
Campagnoli C., Ambroggio S., Lotano M. R., Peris C. Progestogen use in women approaching the menopause and breast cancer risk. Maturitas. 2009;62(4):338-42. NRQ. [pmid: 19118958].
Campbell P. T., Newcomb P., Gallinger S., Cotterchio M., McLaughlin J. R. Exogenous hormones and colorectal cancer risk in Canada: associations stratified by clinically defined familial risk of cancer. Cancer Causes Control. 2007;18(7):723-33. DES. [pmid: 17549595].
Campbell S., Whitehead M. Oestrogen therapy and the menopausal syndrome. Clin Obstet Gynaecol. 1977;4(1):31-47. NRF. [pmid: 322905].
Cancelo Hidalgo M. J., Castelo Branco C. Optimizing soy isoflavones effect in postmenopausal women: The impact of timing on climacteric symptoms. Gynecological Endocrinology. 2011;27(9):696-700. NRQ. [pmid: 20979541].
Canchola A. J., Chang E. T., Bernstein L., Largent J. A., Reynolds P., Deapen D., Ursin G., Horn-Ross P. L. Body size and the risk of endometrial cancer by hormone therapy use in postmenopausal women in the California Teachers Study cohort. Cancer Causes Control. 2010;21(9):1407-16. DES. [pmid: 20431936].
Canchola A. J., Chang E. T., Bernstein L., Largent J. A., Reynolds P., Deapen D., Henderson K. D., Ursin G., Horn-Ross P. L. Body size and the risk of ovarian cancer by hormone therapy use in the California Teachers Study cohort. Cancer Causes Control. 2010;21(12):2241-8. DES. [pmid: 20924664].
Canderelli R., Leccesse L. A., Miller N. L., Unruh Davidson J. Benefits of hormone replacement therapy in postmenopausal women. J Am Acad Nurse Pract. 2007;19(12):635-41. NCT. [pmid: 18042129].
Cano A., Garcia-Perez M. A., Tarin J. J. Isoflavones and cardiovascular disease. Maturitas. 2010;67(3):219-26. NCT. [pmid: 20728290].
Canonico M., Fournier A., Carcaillon L., Olie V., Plu-Bureau G., Oger E., Mesrine S., Boutron-Ruault M. C., Clavel-Chapelon F., Scarabin P. Y. Postmenopausal hormone therapy and risk of idiopathic venous thromboembolism: results from the E3N cohort study. Arterioscler Thromb Vasc Biol. 2010;30(2):340-5. DES. [pmid: 19834106].
Canonico M., Oger E., Plu-Bureau G., Conard J., Meyer G., Levesque H., Trillot N., Barrellier M. T., Wahl D., Emmerich J., Scarabin P. Y. Hormone therapy and venous thromboembolism among postmenopausal women: impact of the route of estrogen administration and progestogens: the ESTHER study. Circulation. 2007;115(7):840-5. DES. [pmid: 17309934].
Canonico M., Oger E., Conard J., Meyer G., Levesque H., Trillot N., Barrellier M. T., Wahl D., Emmerich J., Scarabin P. Y. Obesity and risk of venous thromboembolism among postmenopausal women: differential impact of hormone therapy by route of estrogen administration. The ESTHER Study. J Thromb Haemost. 2006;4(6):1259-65. DES. [pmid: 16706969].
Canonico M., Plu-Bureau G., Scarabin P. Y. Progestogens and venous thromboembolism among postmenopausal women using hormone therapy. Maturitas. 2011;70(4):354-60. NCT. [pmid: 22024394].
Canonico M., Plu-Bureau G., Lowe D., Scarabin P. Y. Hormone replacement therapy and risk of venous thromboembolism in postmenopausal women: systematic review and meta-analysis. BMJ. 2008;336(7655):1227-31. PTU. [pmid: 18495631].
Capobianco G., Donolo E., Borghero G., Dessole F., Cherchi P. L., Dessole S. Effects of intravaginal estriol and pelvic floor rehabilitation on urogenital aging in postmenopausal women. Arch Gynecol Obstet. 2012;285(2):397-403. NRQ. [pmid: 21706345].
Capobianco G., Donolo E., Farina M., Dessole F., Cherchi C., Dessole M., Cherchi P. L. Effects of intravaginal estriol and pelvic floor rehabilitation on urogenital aging in postmenopausal women. International Journal of Gynecology and Obstetrics. 2012;119:S306. DUP.
Cardozo L., Bachmann G., McClish D., Fonda D., Birgerson L. Meta-analysis of estrogen therapy in the management of urogenital atrophy in postmenopausal women: second report of the Hormones and Urogenital Therapy Committee. Obstet Gynecol. 1998;92(4 Pt 2):722-7. NRD. [pmid: 9764689].
Carmignani L. O., Pedro A. O., Costa-Paiva L. H., Pinto-Neto A. M. The effect of dietary soy supplementation compared to estrogen and placebo on menopausal symptoms: a randomized controlled trial. Maturitas. 2010;67(3):262-9. NOP. [pmid: 20833488].
Carpenter J. S., Guthrie K. A., Larson J. C., Freeman E. W., Joffe H., Reed S. D., Ensrud K. E., LaCroix A. Z. Effect of escitalopram on hot flash interference: a randomized, controlled trial. Fertil Steril. 2012;97(6):1399-404 e1. DUP. [pmid: 22480818].
Casagrande J., Gerkins V., Henderson B. E., Mack T., Pike M. C. Exogenous estrogens and breast cancer in women with natural menopause. J Natl Cancer Inst. 1976;56(4):839-41. DES. [pmid: 1255802].
Cassidy A., Albertazzi P., Lise Nielsen I., Hall W., Williamson G., Tetens I., Atkins S., Cross H., Manios Y., Wolk A., Steiner C., Branca F. Critical review of health effects of soyabean phyto-oestrogens in post-menopausal women. Proc Nutr Soc. 2006;65(1):76-92. NRD. [pmid: 16441947].
Castellsague J., Perez Gutthann S., Garcia Rodriguez L. A. Recent epidemiological studies of the association between hormone replacement therapy and venous thromboembolism. A review. Drug Saf. 1998;18(2):117-23. NCT. [pmid: 9512918].
Castelo-Branco C., Soveral I. Phytoestrogens and bone health at different reproductive stages. Gynecol Endocrinol. 2013. NRO.
Castelo-Branco C., Cancelo M. J. Compounds for the treatment of atropic vaginitis. Expert Opinion on Therapeutic Patents. 2008;18(12):1385-1394. NRD.
Castelo-Branco C., Cancelo Hidalgo M. J. Isoflavones: effects on bone health. Climacteric. 2011;14(2):204-11. NRO. [pmid: 21083367].
Cauley J. A., Seeley D. G., Ensrud K., Ettinger B., Black D., Cummings S. R. Estrogen replacement therapy and fractures in older women. Study of Osteoporotic Fractures Research Group. Ann Intern Med. 1995;122(1):9-16. DES. [pmid: 7985914].
Cauley J. A., Black D. M., Barrett-Connor E., Harris F., Shields K., Applegate W., Cummings S. R. Effects of hormone replacement therapy on clinical fractures and height loss: The Heart and Estrogen/Progestin Replacement Study (HERS). Am J Med. 2001;110(6):442-50. DES. [pmid: 11331055].
Cauley J. A., Robbins J., Chen Z., Cummings S. R., Jackson R. D., LaCroix A. Z., LeBoff M., Lewis C. E., McGowan J., Neuner J., Pettinger M., Stefanick M. L., Wactawski-Wende J., Watts N. B. Effects of estrogen plus progestin on risk of fracture and bone mineral density: the Women's Health Initiative randomized trial. JAMA. 2003;290(13):1729-38. DES. [pmid: 14519707].
Chang A., Kwak B. Y., Yi K., Kim J. S. The effect of herbal extract (EstroG-100) on pre-, peri- and post-menopausal women: a randomized double-blind, placebo-controlled study. Phytother Res. 2012;26(4):510-6. DUP. [pmid: 21887807].
Chang C., Lin C. H. Hormone replacement therapy and menopause: a review of randomized, double-blind, placebo-controlled trials. Kaohsiung J Med Sci. 2003;19(6):257-70. NRO. [pmid: 12873034].
Chang S. C., Lacey J. V. Jr., Brinton L. A., Hartge P., Adams K., Mouw T., Carroll L., Hollenbeck A., Schatzkin A., Leitzmann M. F. Lifetime weight history and endometrial cancer risk by type of menopausal hormone use in the NIH-AARP diet and health study. Cancer Epidemiol Biomarkers Prev. 2007;16(4):723-30. DES. [pmid: 17416763].
Chapurlat R. D., Bauer D. C., Nevitt M., Stone K., Cummings S. R. Incidence and risk factors for a second hip fracture in elderly women. The Study of Osteoporotic Fractures. Osteoporos Int. 2003;14(2):130-6. DES. [pmid: 12730779].
Checa M. A., Garrido A., Prat M., Conangla M., Rueda C., Carreras R. A comparison of raloxifene and calcium plus vitamin D on vaginal atrophy after discontinuation of long-standing postmenopausal hormone therapy in osteoporotic women. A randomized, masked-evaluator, one-year, prospective study. Maturitas. 2005;52(1):70-7. NRC. [pmid: 16143228].
Chedraui P., Hidalgo L., San Miguel G., Morocho N., Ross S. Red clover extract (MF11RCE) supplementation and postmenopausal vaginal and sexual health. Int J Gynaecol Obstet. 2006;95(3):296-7. DUP. [pmid: 17007858].
Cheema D., Coomarasamy A., El-Toukhy T. Non-hormonal therapy of post-menopausal vasomotor symptoms: a structured evidence-based review. Arch Gynecol Obstet. 2007;276(5):463-9. NRD. [pmid: 17593379].
Chen H. Y., Cho W. C., Sze C., Tong Y. Treatment of menopausal symptoms with Er-xian decoction: a systematic review. Am J Chin Med. 2008;36(2):233-44. NRD. [pmid: 18457358].
Chen J., Geng L., Song X., Li H., Giordan N., Liao Q. Evaluation of the efficacy and safety of hyaluronic Acid vaginal gel to ease vaginal dryness: a multicenter, randomized, controlled, open-label, parallel-group, clinical trial. J Sex Med. 2013;10(6):1575-84. NRF. [pmid: 23574713].
Chen L. C., Tsao Y. T., Yen K. Y., Chen Y. F., Chou H., Lin M. F. A pilot study comparing the clinical effects of Jia-Wey Shiau-Yau San, a traditional Chinese herbal prescription, and a continuous combined hormone replacement therapy in postmenopausal women with climacteric symptoms. Maturitas. 2003;44(1):55-62. NOP. [pmid: 12568736].
Chen W. Y., Colditz G. A., Rosner B., Hankinson S. E., Hunter D. J., Manson J. E., Stampfer M. J., Willett W. C., Speizer F. E. Use of postmenopausal hormones, alcohol, and risk for invasive breast cancer. Ann Intern Med. 2002;137(10):798-804. DES. [pmid: 12435216].
Chen W. Y., Manson J. E., Hankinson S. E., Rosner B., Holmes M. D., Willett W. C., Colditz G. A. Unopposed estrogen therapy and the risk of invasive breast cancer. Arch Intern Med. 2006;166(9):1027-32. DES. [pmid: 16682578].
Chen W. Y., Hankinson S. E., Schnitt S. J., Rosner B. A., Holmes M. D., Colditz G. A. Association of hormone replacement therapy to estrogen and progesterone receptor status in invasive breast carcinoma. Cancer. 2004;101(7):1490-500. DES. [pmid: 15378477].
Cheng G., Butler R., Warner M., Gustafsson J. A., Wilczek B., Landgren B. M. Effects of short-term estradiol and norethindrone acetate treatment on the breasts of normal postmenopausal women. Menopause. 2013;20(5):496-503. NRO. [pmid: 23615640].
Cheng R. J., Dupont C., Archer D. F., Bao W., Racketa J., Constantine G., Pickar J. H. Effect of desvenlafaxine on mood and climacteric symptoms in menopausal women with moderate to severe vasomotor symptoms. Climacteric. 2013;16(1):17-27. DUP. [pmid: 22646219].
Chiechi L. M., Micheli L. Utility of dietary phytoestrogens in preventing postmenopausal osteoporosis. Current Topics in Nutraceutical Research. 2005;3(1):15-28. NRO.
Chiu C. L., Lind J. M. Menopausal hormone therapy: Examining cardiovascular and clinical impacts of treatment. Future Cardiology. 2013;9(3):427-435. NCT. [pmid: 23668745].
Chlebowski R. T., Anderson G. L. Changing concepts: Menopausal hormone therapy and breast cancer. J Natl Cancer Inst. 2012;104(7):517-27. NCT. [pmid: 22427684].
Chlebowski R. T., Anderson G., Manson J. E., Pettinger M., Yasmeen S., Lane D., Langer R. D., Hubbell F. A., McTiernan A., Hendrix S., Schenken R., Stefanick M. L. Estrogen alone in postmenopausal women and breast cancer detection by means of mammography and breast biopsy. J Clin Oncol. 2010;28(16):2690-7. DES. [pmid: 20439627].
Chlebowski R. T., Anderson G. L., Gass M., Lane D. S., Aragaki A. K., Kuller L. H., Manson J. E., Stefanick M. L., Ockene J., Sarto G. E., Johnson K. C., Wactawski-Wende J., Ravdin P. M., Schenken R., Hendrix S. L., Rajkovic A., Rohan T. E., Yasmeen S., Prentice R. L. Estrogen plus progestin and breast cancer incidence and mortality in postmenopausal women. JAMA. 2010;304(15):1684-92. DES. [pmid: 20959578].
Chlebowski R. T., Wactawski-Wende J., Ritenbaugh C., Hubbell F. A., Ascensao J., Rodabough R. J., Rosenberg C. A., Taylor V. M., Harris R., Chen C., Adams-Campbell L. L., White E. Estrogen plus progestin and colorectal cancer in postmenopausal women. N Engl J Med. 2004;350(10):991-1004. DES. [pmid: 14999111].
Chlebowski R. T., Kuller L. H., Prentice R. L., Stefanick M. L., Manson J. E., Gass M., Aragaki A. K., Ockene J. K., Lane D. S., Sarto G. E., Rajkovic A., Schenken R., Hendrix S. L., Ravdin P. M., Rohan T. E., Yasmeen S., Anderson G. Breast cancer after use of estrogen plus progestin in postmenopausal women. N Engl J Med. 2009;360(6):573-87. DES. [pmid: 19196674].
Chlebowski R. T., Hendrix S. L., Langer R. D., Stefanick M. L., Gass M., Lane D., Rodabough R. J., Gilligan M. A., Cyr M. G., Thomson C. A., Khandekar J., Petrovitch H., McTiernan A. Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women's Health Initiative Randomized Trial. JAMA. 2003;289(24):3243-53. DES. [pmid: 12824205].
Chollet J. A. Efficacy and safety of ultra-low-dose Vagifem (10 mcg). Patient Prefer Adherence. 2011;5:571-4. NCT. [pmid: 22163155].
Christensen M. S., Hagen C., Christiansen C., Transbol I. Dose-response evaluation of cyclic estrogen/gestagen in postmenopausal women: placebo-controlled trial of its gynecologic and metabolic actions. Am J Obstet Gynecol. 1982;144(8):873-9. NOP. [pmid: 6756151].
Chubak J., Doherty J. A., Cushing-Haugen K. L., Voigt L. F., Saltzman B. S., Hill D. A., Beresford S. A., Weiss N. S. Endometrial cancer risk in estrogen users after switching to estrogen-progestin therapy. Cancer Causes Control. 2007;18(9):1001-7. DES. [pmid: 17653829].
Cianci A., Cicero A. F., Colacurci N., Matarazzo M. G., De Leo V. Activity of isoflavones and berberine on vasomotor symptoms and lipid profile in menopausal women. Gynecol Endocrinol. 2012;28(9):699-702. DUP. [pmid: 22313171].
Cirigliano M. Bioidentical hormone therapy: a review of the evidence. J Womens Health (Larchmt). 2007;16(5):600-31. NRC. [pmid: 17627398].
Cirillo D. J., Wallace R. B., Rodabough R. J., Greenland P., LaCroix A. Z., Limacher M. C., Larson J. C. Effect of estrogen therapy on gallbladder disease. JAMA. 2005;293(3):330-9. DES. [pmid: 15657326].
Clarke S. C., Kelleher J., Lloyd-Jones H., Slack M., Schofiel P. M. A study of hormone replacement therapy in postmenopausal women with ischaemic heart disease: the Papworth HRT atherosclerosis study. BJOG. 2002;109(9):1056-62. DES. [pmid: 12269682].
Clarkson T. B., Melendez G. C., Appt S. E. Timing hypothesis for postmenopausal hormone therapy: Its origin, current status, and future. Menopause. 2013;20(3):342-353. NCT. [pmid: 23435033].
Clarkson T. B., Utian W. H., Barnes S., Gold E. B., Basaria S. S., Aso T., Kronenberg F., Frankenfeld C. L., Cline J. M. A., Landgren B. M., Gallagher J. C., Weaver C. M., Hodis H. N., Brinton R. D., Maki P. M., Setchell K. D. R., Setchell D. R., Allmen T. I., Messina M. J., Shu X. O., Ishimi Y., Wong W. W., Kim H. The role of soy isoflavones in menopausal health: Report of the North American Menopause Society/Wulf Utian H. Translational Science Symposium in Chicago, IL (October 2010). Menopause. 2011;18(7):732-753. NRD. [pmid: 21685820].
Clayton A. H., Kornstein S. G., Dunlop B. W., Focht K., Musgnung J., Ramey T., Bao W., Ninan P. T. Efficacy and safety of desvenlafaxine 50 mg/d in a randomized, placebo-controlled study of perimenopausal and postmenopausal women with major depressive disorder. Journal of Clinical Psychiatry. 2013;74:1010-1017. NRP. [pmid: 24229754].
Clonidine, gabapentin, and some SSRIs effective for hot flashes. Journal of Family Practice. 2006;55(8):662. NRD. [pmid: 17152139].
Clonidine, gabapentin, and some SSRIs effective for hot ashes. South African Family Practice. 2006;48(6):13. NRD.
Col N. F., Bowlby L. A., McGarry K. The role of menopausal hormone therapy in preventing osteoporotic fractures: a critical review of the clinical evidence. Minerva Med. 2005;96(5):331-42. DES. [pmid: 16227948].
Colditz G. A., Stampfer M. J., Willett W. C., Hennekens C. H., Rosner B., Speizer F. E. Prospective study of estrogen replacement therapy and risk of breast cancer in postmenopausal women. JAMA. 1990;264(20):2648-53. DES. [pmid: 2232041].
Colditz G. A., Stampfer M. J., Willett W. C., Hunter D. J., Manson J. E., Hennekens C. H., Rosner B. A., Speizer F. E. Type of postmenopausal hormone use and risk of breast cancer: 12-year follow-up from the Nurses' Health Study. Cancer Causes Control. 1992;3(5):433-9. DES. [pmid: 1525324].
Colditz G. A., Hankinson S. E., Hunter D. J., Willett W. C., Manson J. E., Stampfer M. J., Hennekens C., Rosner B., Speizer F. E. The use of estrogens and progestins and the risk of breast cancer in postmenopausal women. N Engl J Med. 1995;332(24):1589-93. DES. [pmid: 7753136].
Colditz G. A., Willett W. C., Stampfer M. J., Rosner B., Speizer F. E., Hennekens C. H. Menopause and the risk of coronary heart disease in women. N Engl J Med. 1987;316(18):1105-10. DES. [pmid: 3574358].
Collins J. A., Blake J. M., Crosignani P. G. Breast cancer risk with postmenopausal hormonal treatment. Hum Reprod Update. 2005;11(6):545-60. PTU. [pmid: 16150813].
Compston J. E., Watts N. B. Combination therapy for postmenopausal osteoporosis. Clin Endocrinol (Oxf). 2002;56(5):565-9. NRO. [pmid: 12030903].
Conaway E. Bioidentical hormones: an evidence-based review for primary care providers. J Am Osteopath Assoc. 2011;111(3):153-64. NCT. [pmid: 21464264].
Conjugated equine oestrogen increases the risk of venous thrombosis in post-menopausal women. Evidence-Based Healthcare and Public Health. 2005;9(2):161-162. DES.
Conjugated equine estradiol and 17(beta)-estradiol effectively relieve hot flashes in menopausal women. Evidence-Based Healthcare and Public Health. 2004;8(5):310-311. NRD.
O'Connell D., Robertson J., Henry D., Gillespie W. A systematic review of the skeletal effects of estrogen therapy in postmenopausal women. I An I. assessment of treatment effects. Climacteric. 1998;1(2):112-23. NRO. [pmid: 11907914].
Cook N. R., Rosner B. A., Hankinson S. E., Colditz G. A. Mammographic screening and risk factors for breast cancer. Am J Epidemiol. 2009;170(11):1422-32. DES. [pmid: 19875646].
Coon J. T., Pittler M. H., Ernst E. Trifolium pratense isoflavones in the treatment of menopausal hot flushes: a systematic review and meta-analysis. Phytomedicine. 2007;14(2-3):153-9. NRD. [pmid: 17239573].
Cooper W., Marnie M., Daw E. A clinical trial of piperazine oestrone sulphate ('Harmogen') in the treatment of menopausal symptoms. Curr Med Res Opin. 1974;2(5):260-3. NOP. [pmid: 4411586].
Corrao G., Zambon A., Conti V., Nicotra F., La Vecchia C., Fornari C., Cesana G., Contiero P., Tagliabue G., Nappi R. E., Merlino L. Menopause hormone replacement therapy and cancer risk: an Italian record linkage investigation. Ann Oncol. 2008;19(1):150-5. DES. [pmid: 17785762].
Cortes-Prieto J., Juez-Martel P. Incidences of breast cancer throughout long-term hormone replacement therapy. J Steroid Biochem Mol Biol. 2007;104(3-5):180-9. DES. [pmid: 17467269].
Crandall C. J., Aragaki A. K., Cauley J. A., McTiernan A., Manson J. E., Anderson G., Chlebowski R. T. Breast tenderness and breast cancer risk in the estrogen plus progestin and estrogen-alone women's health initiative clinical trials. Breast Cancer Research and Treatment. 2012;132(1):275-285. NRQ. [pmid: 22042371].
Crandall C. J., Aragaki A. K., Chlebowski R. T., McTiernan A., Anderson G., Hendrix S. L., Cochrane B. B., Kuller L. H., Cauley J. A. New-onset breast tenderness after initiation of estrogen plus progestin therapy and breast cancer risk. Arch Intern Med. 2009;169(18):1684-91. DES. [pmid: 19822825].
Cranney A., Guyatt G., Griffith L., Wells G., Tugwell P., Rosen C. IX: Summary of meta-analyses of therapies for postmenopausal osteoporosis. Endocrine Reviews. 2002;23(4):570-578. PTU. [pmid: 12202472].
Cravioto M. D., Durand-Carbajal M., Jimenez-Santana L., Lara-Reyes P., Seuc A. H., Sanchez-Guerrero J. Efficacy of estrogen plus progestin on menopausal symptoms in women with systemic lupus erythematosus: a randomized, double-blind, controlled trial. Arthritis Care Res (Hoboken). 2011;63(12):1654-63. NRP. [pmid: 22127965].
Crawford S. L., Jackson E. A., Churchill L., Lampe J. W., Leung K., Ockene J. K. Impact of dose, frequency of administration, and equol production on efficacy of isoflavones for menopausal hot flashes: A pilot randomized trial. Menopause. 2013;20:936-945. DUP. [pmid: 23511704].
Crawford-Faucher A. Escitalopram effective for reducing hot flashes in menopausal women. American Family Physician. 2011;84(11):1293-1294. DUP.
Creasman W. T. Is there an association between hormone replacement therapy and breast cancer?. J Womens Health. 1998;7(10):1231-46. NCT. [pmid: 9929856].
Criqui M. H., Suarez L., Barrett-Connor E., McPhillips J., Wingard D. L., Garland C. Postmenopausal estrogen use and mortality. Results from a prospective study in a defined, homogeneous community. Am J Epidemiol. 1988;128(3):606-14. DES. [pmid: 3414664].
Crosbie E. J., Zwahlen M., Kitchener H. C., Egger M., Renehan A. G. Body mass index, hormone replacement therapy, and endometrial cancer risk: a meta-analysis. Cancer Epidemiol Biomarkers Prev. 2010;19(12):3119-30. DES. [pmid: 21030602].
Curb J. D., Prentice R. L., Bray P. F., Langer R. D., Van Horn L., Barnabei V. M., Bloch M. J., Cyr M. G., Gass M., Lepine L., Rodabough R. J., Sidney S., Uwaifo G. I., Rosendaal F. R. Venous thrombosis and conjugated equine estrogen in women without a uterus. Arch Intern Med. 2006;166(7):772-80. DES. [pmid: 16606815].
Cushing K. L., Weiss N. S., Voigt L. F., McKnight B., Beresford S. A. Risk of endometrial cancer in relation to use of low-dose, unopposed estrogens. Obstet Gynecol. 1998;91(1):35-9. DES. [pmid: 9464717].
Cushman M., Kuller L. H., Prentice R., Rodabough R. J., Psaty B. M., Stafford R. S., Sidney S., Rosendaal F. R. Estrogen plus progestin and risk of venous thrombosis. JAMA. 2004;292(13):1573-80. DES. [pmid: 15467059].
Dalais F. S., Rice G. E., Wahlqvist M. L., Grehan M., Murkies A. L., Medley G., Ayton R., Strauss B. J. Effects of dietary phytoestrogens in postmenopausal women. Climacteric. 1998;1(2):124-9. NOP. [pmid: 11907915].
Daly E., Vessey M. P., Hawkins M. M., Carson J. L., Gough P., Marsh S. Risk of venous thromboembolism in users of hormone replacement therapy. Lancet. 1996;348(9033):977-80. DES. [pmid: 8855852].
Dando T. M., Perry C. M. 17 beta-estradiol/levonorgestrel transdermal system. Treat Endocrinol. 2004;3(5):319-24. DUP. [pmid: 15330679].
Danforth K. N., Tworoger S. S., Hecht J. L., Rosner B. A., Colditz G. A., Hankinson S. E. A prospective study of postmenopausal hormone use and ovarian cancer risk. Br J Cancer. 2007;96(1):151-6. DES. [pmid: 17179984].
Daniele C., Thompson Coon J., Pittler M. H., Ernst E. Vitex agnus castus: a systematic review of adverse events. Drug Saf. 2005;28(4):319-32. NRP. [pmid: 15783241].
Davis S. R., Braunstein G. D. Efficacy and safety of testosterone in the management of hypoactive sexual desire disorder in postmenopausal women. J Sex Med. 2012;9(4):1134-48. NCT. [pmid: 22304681].
Davis S. R., Panjari M., Stanczyk F. Z. DHEA replacement for postmenopausal women. Journal of Clinical Endocrinology and Metabolism. 2011;96(6):1642-1653. NRD. [pmid: 21411558].
Davison S. L., Bell R. J., Robinson P. J., Jane F., Leech J., Maruff P., Egan G. F., Davis S. R. Continuous-combined oral estradiol/drospirenone has no detrimental effect on cognitive performance and improves estrogen deficiency symptoms in early postmenopausal women: a randomized placebo-controlled trial. Menopause. 2013;20:1020-6. NOP. [pmid: 23591255].
De Aloysio D., Fabiani A. G., Mauloni M., Bottiglioni F. Use of Org OD 14 for the treatment of climacteric complaints. Maturitas. Suppl 1. 1987:49-65. NRC. [pmid: 3306291].
DeRogatis L. R., Graziottin A., Bitzer J., Schmitt S., Koochaki P. E., Rodenberg C. Clinically relevant changes in sexual desire, satisfying sexual activity and personal distress as measured by the profile of female sexual function, sexual activity log, and personal distress scale in postmenopausal women with hypoactive sexual desire disorder. J Sex Med. 2009;6(1):175-83. DUP. [pmid: 19170847].
De Leo V., la Marca A., Morgante G., Lanzetta D., Florio P., Petraglia F. Evaluation of combining kava extract with hormone replacement therapy in the treatment of postmenopausal anxiety. Maturitas. 2001;39(2):185-8. NOP. [pmid: 11514117].
Delaune A., Landreneau K., Hire K., Dillard B., Cox M., Payne K., Powell C. Credibility of a meta-analysis: evidence-based practice concerning soy intake and breast cancer risk in premenopausal women. Worldviews Evid Based Nurs. 2009;6(3):160-6. NRQ. [pmid: 19744053].
Delgado-Rodriguez M., Sillero-Arenas M., Rodriguez-Contreras R., Lopez Gigosos R., Galvez Vargas R. Oral contraceptives and breast cancer. A meta-analysis. Rev Epidemiol Sante Publique. 1991;39(2):165-81. NRQ. [pmid: 1830968].
Demetrio F. N., Renno J. Jr., Gianfaldoni A., Goncalves M., Halbe H. W., Filho A. H., Gorenstein C. Effect of estrogen replacement therapy on symptoms of depression and anxiety in non-depressive menopausal women: a randomized double-blind, controlled study. Arch Womens Ment Health. 2011;14(6):479-86. DUP. [pmid: 22016254].
Dennehy C., Tsourounis C. A review of select vitamins and minerals used by postmenopausal women. Maturitas. 2010;66(4):370-80. NRD. [pmid: 20580500].
Dennehy C. E. The use of herbs and dietary supplements in gynecology: an evidence-based review. J Midwifery Womens Health. 2006;51(6):402-9. NCT. [pmid: 17081929].
Dennerstein L., Burrows G. D. Hormone replacement therapy and sexuality in women. Clin Endocrinol Metab. 1982;11(3):661-79. NRD. [pmid: 6814799].
Dew T. P., Williamson G. Controlled flax interventions for the improvement of menopausal symptoms and postmenopausal bone health: a systematic review. Menopause. 2013;20:1207-15. NRD. [pmid: 23571524].
Dew T. P., Williamson G. Controlled flax interventions for the improvement of menopausal symptoms and postmenopausal bone health: a systematic review. Menopause. 2013. NRO.
Diamanti-Kandarakis E. Hormone replacement therapy and risk of malignancy. Curr Opin Obstet Gynecol. 2004;16(1):73-8. NCT. [pmid: 15128011].
Dick S. E., DeWitt D. E., Anawalt B. D. Postmenopausal hormone replacement therapy and major clinical outcomes: a focus on cardiovascular disease, osteoporosis, dementia, and breast and endometrial neoplasia. Am J Manag Care. 2002;8(1):95-104. quiz 105-6. NCT. [pmid: 11814176].
Diem S. J., Ruppert K., Cauley J. A., Lian Y., Bromberger J. T., Finkelstein J. S., Greendale G. A., Solomon D. H. Rates of bone loss among women initiating antidepressant medication use in midlife. J Clin Endocrinol Metab. 2013;98:4355-63. NRO. [pmid: 24001746].
Diem S., Grady D., Quan J., Vittinghoff E., Wallace R., Hanes V., Ensrud K. Effects of ultralow-dose transdermal estradiol on postmenopausal symptoms in women aged 60 to 80 years. Menopause. 2006;13(1):130-8. NRQ. [pmid: 16607109].
Dimitrakakis C., Jones R. A., Liu A., Bondy C. A. Breast cancer incidence in postmenopausal women using testosterone in addition to usual hormone therapy. Menopause. 2004;11(5):531-5. DES. [pmid: 15356405].
Ding E. L., Mehta S., Fawzi W. W., Giovannucci E. L. Interaction of estrogen therapy with calcium and vitamin D supplementation on colorectal cancer risk: reanalysis of Women's Health Initiative randomized trial. Int J Cancer. 2008;122(8):1690-4. DES. [pmid: 18092326].
Dobs A. S., Nguyen T., Pace C., Roberts C. P. Differential effects of oral estrogen versus oral estrogen-androgen replacement therapy on body composition in postmenopausal women. J Clin Endocrinol Metab. 2002;87(4):1509-16. NOP. [pmid: 11932273].
Doherty J. A., Cushing-Haugen K. L., Saltzman B. S., Voigt L. F., Hill D. A., Beresford S. A., Chen C., Weiss N. S. Long-term use of postmenopausal estrogen and progestin hormone therapies and the risk of endometrial cancer. Am J Obstet Gynecol. 2007;197(2):139 e1-7. DES. [pmid: 17689625].
Dong J. Y., Qin L. Q. Soy isoflavones consumption and risk of breast cancer incidence or recurrence: a meta-analysis of prospective studies. Breast Cancer Res Treat. 2011;125(2):315-23. NRD. [pmid: 21113655].
Dooley M., Spencer C. M., Ormrod D. Estradiol-intranasal: a review of its use in the management of menopause. Drugs. 2001;61(15):2243-62. NRD. [pmid: 11772138].
Doren M., Azzawi F. A., Donnez J., Van der Mooren M. J., Villero J., Gompel A. Therapeutic value and long-term safety of pulsed estrogen therapy. Maturitas. Suppl 1. 2001;38:S23-30. DUP. [pmid: 11390121].
Douketis J. D., Julian J. A., Kearon C., Anderson D. R., Crowther M. A., Bates S. M., Barone M., Piovella F., Turpie A. G., Middeldorp S., van Nguyen P., Prandoni P., Wells P. S., Kovacs M. J., MacGillavry M. R., Costantini L., Ginsberg J. S. Does the type of hormone replacement therapy influence the risk of deep vein thrombosis? A prospective case-control study. J Thromb Haemost. 2005;3(5):943-8. DES. [pmid: 15869589].
Dubey G. P., Rajamanickam G. V., Aruna Agrawal A. Neuropsycho-cardiologic risks associated with menopausal women - Benefits of a plant based formulation. Planta Medica. 2009;75(4):453-454. NRO.
Dupont A., Dupont P., Cusan L., Tremblay M., Rioux J., Cloutier D., Mailloux J., De Lignieres B., Gutkowska J., Boucher H., et al. Comparative endocrinological and clinical effects of percutaneous estradiol and oral conjugated estrogens as replacement therapy in menopausal women. Maturitas. 1991;13(4):297-311. NOP. [pmid: 1663571].
Dupont W. D., Page D. L. Menopausal estrogen replacement therapy and breast cancer. Arch Intern Med. 1991;151(1):67-72. PTU. [pmid: 1824675].
Eberhardt S., Kulp W., von der Schulenburg J. M., Willich S. N., Keil T., Greiner W. Hormones for therapy of climacteric afflictions. GMS Health Technol Assess. 2007;3. Doc03. NRD.
Eden J. A. Phytoestrogens for menopausal symptoms: a review. Maturitas. 2012;72(2):157-9. NRD. [pmid: 22516278].
Edington R. F., Chagnon J. P., Steinberg W. M. Clonidine (Dixarit) for menopausal flushing. Can Med Assoc J. 1980;123(1):23-6. NOP. [pmid: 6998552].
Eichner S. F., Lloyd K. B., Timpe E. M. Comparing therapies for postmenopausal osteoporosis prevention and treatment. Ann Pharmacother. 2003;37(5):711-24. PTU. [pmid: 12708951].
Eisen A., Lubinski J., Gronwald J., Moller P., Lynch H. T., Klijn J., Kim-Sing C., Neuhausen S. L., Gilbert L., Ghadirian P., Manoukian S., Rennert G., Friedman E., Isaacs C., Rosen E., Rosen B., Daly M., Sun P., Narod S. A. Hormone therapy and the risk of breast cancer in BRCA1 mutation carriers. J Natl Cancer Inst. 2008;100(19):1361-7. DES. [pmid: 18812548].
Elfituri A., Sherif F., Elmahaishi M., Chrystyn H. Two hormone replacement therapy (HRT) regimens for middle-eastern postmenopausal women. Maturitas. 2005;52(1):52-9. NRC. [pmid: 16143225].
Elhelw B. Non-hormonal therapies for the treatment of menopausal symptoms. Middle East Fertility Society Journal. 2006;11(1):1-17. NRD.
D'Elia H. F., Larsen A., Mattsson L. A., Waltbrand E., Kvist G., Mellstrom D., Saxne T., Ohlsson C., Nordborg E., Carlsten H. Influence of hormone replacement therapy on disease progression and bone mineral density in rheumatoid arthritis. J Rheumatol. 2003;30(7):1456-63. NRO. [pmid: 12858441].
Elit L. Endometrial cancer. Prevention, detection, management, and follow up. Can Fam Physician. 2000;46:887-92. NRQ. [pmid: 10790821].
Engel P., Fabre A., Fournier A., Mesrine S., Boutron-Ruault M. C., Clavel-Chapelon F. Risk of osteoporotic fractures after discontinuation of menopausal hormone therapy: results from the E3N cohort. Am J Epidemiol. 2011;174(1):12-21. DES. [pmid: 21555715].
Ensrud K. E., Joffe H., Guthrie K. A., Larson J. C., Reed S. D., Newton K. M., Sternfeld B., Lacroix A. Z., Landis C. A., Woods N. F., Freeman E. W. Effect of escitalopram on insomnia symptoms and subjective sleep quality in healthy perimenopausal and postmenopausal women with hot flashes: A randomized controlled trial. Menopause. 2012;19(8):848-855. DUP. [pmid: 22433978].
Ensrud K., Larson J., Guthrie K., Joffe H., La Croix A., Landis C., Newton K., Reed S., Sternfield B., Woods N., Freeman E. Effect of escitalopram on insomnia symptoms and subjective sleep quality in healthy menopausal women with hot flashes: A randomized controlled trial in the msflash network. Menopause. 2011;18(12):1346. DUP.
Epstein E. P., Lindqvist G., Olsson H. A population-based cohort study on the use of hormone treatment and endometrial cancer in southern Sweden. Int J Cancer. 2009;125(2):421-5. DES. [pmid: 19326453].
Erkkola R., Vervarcke S., Vansteelandt S., Rompotti P., De Keukeleire D., Heyerick A. A randomized, double-blind, placebo-controlled, cross-over pilot study on the use of a standardized hop extract to alleviate menopausal discomforts. Phytomedicine. 2010;17(6):389-96. NOP. [pmid: 20167461].
Espie M., Mares P., de Reilhac P., Chevallier T., Daures J. P. Breast cancer in postmenopausal women with and without hormone replacement therapy: preliminary results of the MISSION study. Gynecol Endocrinol. 2006;22(8):423-31. DES. [pmid: 17012103].
Ettinger B. Use of low-dosage 17 beta-estradiol for the prevention of osteoporosis. Clin Ther. 1993;15(6):950-62. discussion 949. NOP. [pmid: 8111815].
Ettinger B. Vasomotor symptom relief versus unwanted effects: role of estrogen dosage. Am J Med. Suppl 12B. 2005;118:74-8. NCT. [pmid: 16414330].
Ewertz M., Mellemkjaer L., Poulsen A. H., Friis S., Sorensen H. T., Pedersen L., McLaughlin J. K., Olsen J. H. Hormone use for menopausal symptoms and risk of breast cancer. A Danish cohort study. Br J Cancer. 2005;92(7):1293-7. DES. [pmid: 15785751].
Fabre A., Fournier A., Mesrine S., Desreux J., Gompel A., Boutron-Ruault M. C., Clavel-Chapelon F. Oral progestagens before menopause and breast cancer risk. Br J Cancer. 2007;96(5):841-4. DES. [pmid: 17299388].
Fait T., Vrablik M. Coronary heart disease and hormone replacement therapy - from primary and secondary prevention to the window of opportunity. Neuro Endocrinol Lett. 2012;33(Suppl2):17-21. NCT. [pmid: 23183504].
Farquhar C., Marjoribanks J., Lethaby A., Suckling J.A., Lamberts Q. Long term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database Syst Rev. 2009;(2):CD004143. PTU. [pmid: 19370593].
Fernandez E., La Vecchia C., Braga C., Talamini R., Negri E., Parazzini F., Franceschi S. Hormone replacement therapy and risk of colon and rectal cancer. Cancer Epidemiol Biomarkers Prev. 1998;7(4):329-33. DES. [pmid: 9568789].
Fernandez E., La Vecchia C., Franceschi S., Braga C., Talamini R., Negri E., Parazzini F. Oral contraceptive use and risk of colorectal cancer. Epidemiology. 1998;9(3):295-300. DES. [pmid: 9583422].
Fernandez E., Gallus S., Bosetti C., Franceschi S., Negri E., La Vecchia C. Hormone replacement therapy and cancer risk: a systematic analysis from a network of case-control studies. Int J Cancer. 2003;105(3):408-12. NRD. [pmid: 12704678].
Figueiredo J. C., Haile R. W., Bernstein L., Malone K. E., Largent J., Langholz B., Lynch C. F., Bertelsen L., Capanu M., Concannon P., Borg A., Borresen-Dale A. L., Diep A., Teraoka S., Torngren T., Xue S., Bernstein J. L. Oral contraceptives and postmenopausal hormones and risk of contralateral breast cancer among BRCA1 and BRCA2 mutation carriers and noncarriers: the WECARE Study. Breast Cancer Res Treat. 2010;120(1):175-83. DES. [pmid: 19597986].
Finckh A., Berner I. C., Aubry-Rozier B., So A. K. A randomized controlled trial of dehydroepiandrosterone in postmenopausal women with fibromyalgia. J Rheumatol. 2005;32(7):1336-40. NRP. [pmid: 15996074].
Flaxseed consumption reduces menopausal symptoms. Oncology Report. 2005;(SPRING):133. NCT.
Floter A., Nathorst-Boos J., Carlstrom K., von Schoultz B. Addition of testosterone to estrogen replacement therapy in oophorectomized women: effects on sexuality and well-being. Climacteric. 2002;5(4):357-65. NOP. [pmid: 12626215].
Flower G., Fritz H., Balneaves L. G., Verma S., Skidmore B., Fernandes R., Kennedy D., Cooley K., Wong R., Sagar S., Fergusson D., Seely D. Flax and Breast Cancer: A Systematic Review. Integr Cancer Ther. 2013. NRP.
Foidart J. M., Beliard A., Hedon B., Ochsenbein E., Bernard A. M., Bergeron C., Thomas J. L. Impact of percutaneous oestradiol gels in postmenopausal hormone replacement therapy on clinical symptoms and endometrium. Br J Obstet Gynaecol. 1997;104(3):305-10. NRC. [pmid: 9091006].
Folsom A. R., Anderson J. P., Ross J. A. Estrogen replacement therapy and ovarian cancer. Epidemiology. 2004;15(1):100-4. DES. [pmid: 14712153].
Folsom A. R., Kaye S. A., Potter J. D., Prineas R. J. Association of incident carcinoma of the endometrium with body weight and fat distribution in older women: early findings of the Iowa Women's Health Study. Cancer Res. 1989;49(23):6828-31. DES. [pmid: 2819722].
U.S. Food and Drug Administration. Activella (estradiol/norethindrone acetate) tablets [FDA-approved labeling]. 2006. NRD.
Fournier A., Berrino F., Clavel-Chapelon F. Unequal risks for breast cancer associated with different hormone replacement therapies: results from the E3N cohort study. Breast Cancer Res Treat. 2008;107(1):103-11. DES. [pmid: 17333341].
Fournier A., Berrino F., Riboli E., Avenel V., Clavel-Chapelon F. Breast cancer risk in relation to different types of hormone replacement therapy in the E3N-EPIC cohort. Int J Cancer. 2005;114(3):448-54. DES. [pmid: 15551359].
Fournier A., Mesrine S., Boutron-Ruault M. C., Clavel-Chapelon F. Estrogen-progestagen menopausal hormone therapy and breast cancer: does delay from menopause onset to treatment initiation influence risks?. J Clin Oncol. 2009;27(31):5138-43. DES. [pmid: 19752341].
Franks A. L., Kendrick J. S., Tyler C. W. Jr. Postmenopausal smoking, estrogen replacement therapy, and the risk of endometrial cancer. Am J Obstet Gynecol. 1987;156(1):20-3. DES. [pmid: 3799753].
Fraser D. I., Parsons A., Whitehead M. I., Wordsworth J., Stuart G., Pryse-Davies J. The optimal dose of oral norethindrone acetate for addition to transdermal estradiol: a multicenter study. Fertil Steril. 1990;53(3):460-8. NRO. [pmid: 2407564].
Fritz H., Seely D., Flower G., Skidmore B., Fernandes R., Vadeboncoeur S., Kennedy D., Cooley K., Wong R., Sagar S., Sabri E., Fergusson D. Soy, red clover, and isoflavones and breast cancer: a systematic review. PLoS One. 2013;8:e81968. NRC. [pmid: 24312387].
Fritz H., Seely D., McGowan J., Skidmore B., Fernandes R., Kennedy D. A., Cooley K., Wong R., Sagar S., Balneaves L. G., Fergusson D. Black cohosh and breast cancer: a systematic review. Integr Cancer Ther. 2014;13:12-29. DUP. [pmid: 23439657].
Fugate S. E., Church C. O. Nonestrogen treatment modalities for vasomotor symptoms associated with menopause. Ann Pharmacother. 2004;38(9):1482-99. NRD. [pmid: 15292498].
Furness S., Roberts H., Marjoribanks J., Lethaby A., Hickey M., Farquhar C. Hormone therapy in postmenopausal women and risk of endometrial hyperplasia. Cochrane Database Syst Rev. 2009;(2):CD000402. PTU. [pmid: 19370558].
Gabriel S. R., Carmona L., Roque G., Sanchez M. L., Bonfill X. Hormone replacement therapy for preventing cardiovascular disease in post-menopausal women. Cochrane Database Syst Rev. 2005;(2):CD002229. PTU. [pmid: 15846631].
Gallus S., Negri E., Chatenoud L., Bosetti C., Franceschi S., La Vecchia C. Post-menopausal hormonal therapy and gallbladder cancer risk. Int J Cancer. 2002;99(5):762-3. DES. [pmid: 12115514].
Gambacciani M., Rosano G., Cappagli B., Pepe A., Vitale C., Genazzani A. R. Clinical and metabolic effects of drospirenone-estradiol in menopausal women: a prospective study. Climacteric. 2011;14(1):18-24. NOP. [pmid: 20979461].
Gambrell R. D. Jr. Hormone replacement therapy and breast cancer risk. Arch Fam Med. 1996;5(6):341-8. DES. [pmid: 8640324].
Gapstur S. M., Morrow M., Sellers T. A. Hormone replacement therapy and risk of breast cancer with a favorable histology: results of the Iowa Women's Health Study. JAMA. 1999;281(22):2091-7. DES. [pmid: 10367819].
Garbe E., Levesque L., Suissa S. Variability of breast cancer risk in observational studies of hormone replacement therapy: a meta-regression analysis. Maturitas. 2004;47(3):175-83. PTU. [pmid: 15036487].
Garg P. P., Kerlikowske K., Subak L., Grady D. Hormone replacement therapy and the risk of epithelial ovarian carcinoma: a meta-analysis. Obstet Gynecol. 1998;92(3):472-9. PTU. [pmid: 9721791].
Geller S. E., Shulman L. P., van Breemen R. B., Banuvar S., Zhou Y., Epstein G., Hedayat S., Nikolic D., Krause E. C., Piersen C. E., Bolton J. L., Pauli G. F., Farnsworth N. R. Safety and efficacy of black cohosh and red clover for the management of vasomotor symptoms: a randomized controlled trial. Menopause. 2009;16(6):1156-66. NOP. [pmid: 19609225].
Genazzani A. R., Stomati M., Valentino V., Pluchino N., Pot E., Casarosa E., Merlini S., Giannini A., Luisi M. Effect of 1-year, low-dose DHEA therapy on climacteric symptoms and female sexuality. Climacteric. 2011;14(6):661-8. NOP. [pmid: 21942655].
Gerhardsson de Verdier M., London S. Reproductive factors, exogenous female hormones, and colorectal cancer by subsite. Cancer Causes Control. 1992;3(4):355-60. DES. [pmid: 1617123].
Gertig D. M., Fletcher A. S., English D. R., Macinnis R. J., Hopper J. L., Giles G. G. Hormone therapy and breast cancer: what factors modify the association?. Menopause. 2006;13(2):178-84. DES. [pmid: 16645531].
Gigliotti B., Multinu A., Lai V. R. Role of pivagabine in the treatment of climacteric syndrome. Arzneimittelforschung. 1997;47(11A):1317-21. NRC. [pmid: 9450156].
Gikas P. D., Mokbel K. Phytoestrogens and the risk of breast cancer: a review of the literature. Int J Fertil Womens Med. 2005;50(6):250-8. NRD. [pmid: 16526415].
Glud E., Kjaer S. K., Thomsen B. L., Hogdall C., Christensen L., Hogdall E., Bock J. E., Blaakaer J. Hormone therapy and the impact of estrogen intake on the risk of ovarian cancer. Arch Intern Med. 2004;164(20):2253-9. DES. [pmid: 15534163].
Goh H. H., McCarthy T. G., Dramusic V., Costales A., Junge W., Ratnam S. S. Endocrine effects in Asian postmenopausal women, treated with SH D 461 M and Prempak-C. Maturitas. 1995;21(1):17-25. NRO. [pmid: 7731378].
Gompel A. Micronized progesterone and its impact on the endometrium and breast vs. progestogens. Climacteric. 2012;15(SUPPL.1):18-25. NRQ. [pmid: 22432812].
Gompel A., Santen R. J. Hormone therapy and breast cancer risk 10 years after the WHI. Climacteric. 2012;15(3):241-249. NCT. [pmid: 22612610].
Goodman M. T., Cologne J. B., Moriwaki H., Vaeth M., Mabuchi K. Risk factors for primary breast cancer in Japan: 8-year follow-up of atomic bomb survivors. Prev Med. 1997;26(1):144-53. DES. [pmid: 9010910].
Gordon A. Red clover extracts not effective for hot flushes. Journal of Family Practice. 2003;52(11):846-848. NCT. [pmid: 14599376].
Gordon P. R., Kerwin J. P., Boesen K. G., Senf J. Sertraline to treat hot flashes: a randomized controlled, double-blind, crossover trial in a general population. Menopause. 2006;13(4):568-75. NRC. [pmid: 16837878].
Gordon S. F., Thompson K. A., Ruoff G. E., Imig J. R., Lane P. J., Schwenker C. E. Efficacy and safety of a seven-day, transdermal estradiol drug-delivery system: comparison with conjugated estrogens and placebo. The Transdermal Estradiol Patch Study Group. Int J Fertil Menopausal Stud. 1995;40(3):126-34. NRF. [pmid: 7663539].
Gordon S., Walsh B. W., Ciaccia A. V., Siddhanti S., Rosen A. S., Plouffe L. Jr. Transition from estrogen-progestin to raloxifene in postmenopausal women: effect on vasomotor symptoms. Obstet Gynecol. 2004;103(2):267-73. NRQ. [pmid: 14754694].
Grabrick D. M., Hartmann L. C., Cerhan J. R., Vierkant R. A., Therneau T. M., Vachon C. M., Olson J. E., Couch F. J., Anderson K. E., Pankratz V. S., Sellers T. A. Risk of breast cancer with oral contraceptive use in women with a family history of breast cancer. JAMA. 2000;284(14):1791-8. DES. [pmid: 11025831].
Grady D., Herrington D., Bittner V., Blumenthal R., Davidson M., Hlatky M., Hsia J., Hulley S., Herd A., Khan S., Newby L. K., Waters D., Vittinghoff E., Wenger N. Cardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/progestin Replacement Study follow-up (HERS II). JAMA. 2002;288(1):49-57. DES. [pmid: 12090862].
Grady D., Wenger N. K., Herrington D., Khan S., Furberg C., Hunninghake D., Vittinghoff E., Hulley S. Postmenopausal hormone therapy increases risk for venous thromboembolic disease. The Heart and Estrogen/progestin Replacement Study. Ann Intern Med. 2000;132(9):689-96. DES. [pmid: 10787361].
Grady D., Gebretsadik T., Kerlikowske K., Ernster V., Petitti D. Hormone replacement therapy and endometrial cancer risk: a meta-analysis. Obstet Gynecol. 1995;85(2):304-13. PTU. [pmid: 7824251].
Graff-Iversen S., Hammar N., Thelle D. S., Tonstad S. Hormone therapy and mortality during a 14-year follow-up of 14 324 Norwegian women. J Intern Med. 2004;256(5):437-45. DES. [pmid: 15485480].
Graser T., Muller A., Druckman R., Oettel M. Effects of a combination of 2 MG estradiol valerate and 3 MG dienogest on coagulation, lipid profile, and glucose metabolism in postmenopausal women. Drugs of Today. 2001;37(SUPPL. G):87-99. NRO.
Graser T., Muller A., Mellinger U., Muck A. O., Lippert T. H., Oettel M. Continuous-combined treatment of the menopause with combinations of oestradiol valerate and dienogest - a dose-ranging study. Maturitas. 2000;35(3):253-61. NOP. [pmid: 10936742].
Graser T., Rossner P., Schubert K., Muller A., Bonisch U., Oettel M. A comparative study of two levonorgestrel-containing hormone replacement therapy regimens of efficacy and tolerability variables. Maturitas. 1997;28(2):169-79. NRC. [pmid: 9522325].
Graser T., Romer T., Wiedey K. D., Janaud A. Climodien (estradiol valerate 2 mg plus dienogest 2 mg) is safe and effective in the treatment of postmenopausal complaints. Climacteric. 2001;4(4):332-42. NRQ. [pmid: 11770190].
Graziottin A., Serafini A. Depression and the menopause: why antidepressants are not enough?. Menopause Int. 2009;15(2):76-81. NRD. [pmid: 19465674].
Green J., Czanner G., Reeves G., Watson J., Wise L., Roddam A., Beral V. Menopausal hormone therapy and risk of gastrointestinal cancer: Nested case-control study within a prospective cohort, and meta-analysis. International Journal of Cancer. 2011;7(6). NRD.
Greendale G. A., Reboussin B. A., Hogan P., Barnabei V. M., Shumaker S., Johnson S., Barrett-Connor E. Symptom relief and side effects of postmenopausal hormones: results from the Postmenopausal Estrogen/Progestin Interventions Trial. Obstet Gynecol. 1998;92(6):982-8. NRO. [pmid: 9840563].
Greenwald P., Caputo T. A., Wolfgang P. E. Endometrial cancer after menopausal use of estrogens. Obstet Gynecol. 1977;50(2):239-43. DES. [pmid: 876565].
Greiser C. M., Greiser E. M., Doren M. Menopausal hormone therapy and risk of ovarian cancer: systematic review and meta-analysis. Hum Reprod Update. 2007;13(5):453-63. PTU. [pmid: 17573406].
Greiser C. M., Greiser E. M., Doren M. Menopausal hormone therapy and risk of breast cancer: a meta-analysis of epidemiological studies and randomized controlled trials. Hum Reprod Update. 2005;11(6):561-73. PTU. [pmid: 16150812].
Griesser H., Skonietzki S., Fischer T., Fielder K., Suesskind M. Low dose estriol pessaries for the treatment of vaginal atrophy: a double-blind placebo-controlled trial investigating the efficacy of pessaries containing 0.2mg and 0.03mg estriol. Maturitas. 2012;71(4):360-8. NRO. [pmid: 22285095].
Griesser H., Skonietzki S., Fischer T., Fielder K., Suesskind M. Low dose estriol pessaries for the treatment of vaginal atrophy: A double-blind placebo-controlled trial investigating the efficacy of pessaries containing 0.2 mg and 0.03 mg estriol. Maturitas. 2012;71(4):360-368. NRO. [pmid: 22285095].
Grimes D. A., Lobo R. A. Perspectives on the Women's Health Initiative trial of hormone replacement therapy. Obstet Gynecol. 2002;100(6):1344-53. NCT. [pmid: 12468183].
Grodstein F., Stampfer M. J. Estrogen for women at varying risk of coronary disease. Maturitas. 1998;30(1):19-26. NCT. [pmid: 9819779].
Grodstein F., Colditz G. A., Stampfer M. J. Postmenopausal hormone use and cholecystectomy in a large prospective study. Obstet Gynecol. 1994;83(1):5-11. DES. [pmid: 8272307].
Grodstein F., Manson J. E., Stampfer M. J. Hormone therapy and coronary heart disease: the role of time since menopause and age at hormone initiation. J Womens Health (Larchmt). 2006;15(1):35-44. DES. [pmid: 16417416].
Grodstein F., Manson J. E., Stampfer M. J., Rexrode K. Postmenopausal hormone therapy and stroke: role of time since menopause and age at initiation of hormone therapy. Arch Intern Med. 2008;168(8):861-6. DES. [pmid: 18443262].
Grodstein F., Stampfer M. J., Falkeborn M., Naessen T., Persson I. Postmenopausal hormone therapy and risk of cardiovascular disease and hip fracture in a cohort of Swedish women. Epidemiology. 1999;10(5):476-80. DES. [pmid: 10468418].
Grodstein F., Stampfer M. J., Goldhaber S. Z., Manson J. E., Colditz G. A., Speizer F. E., Willett W. C., Hennekens C. H. Prospective study of exogenous hormones and risk of pulmonary embolism in women. Lancet. 1996;348(9033):983-7. DES. [pmid: 8855854].
Grodstein F., Newcomb P. A., Stampfer M. J. Postmenopausal hormone therapy and the risk of colorectal cancer: a review and meta-analysis. Am J Med. 1999;106(5):574-82. PTU. [pmid: 10335731].
Guidozzi F., Daponte A. Estrogen replacement therapy for ovarian carcinoma survivors: A randomized controlled trial. Cancer. 1999;86(6):1013-8. DES. [pmid: 10491528].
Gupta M., Kohli K. Current status of hormone replacement therapy in post menopausal women. Current Drug Therapy. 2007;2(1):11-15. DES.
Gutteridge D. H., Holzherr M. L., Retallack R. W., Price R. I., Will R. K., Dhaliwal S. S., Faulkner D. L., Stewart G. O., Stuckey B. G., Prince R. L., Criddle R. A., Drury P. J., Tran L., Bhagat C. I., Kent G. N., Jamrozik K. A randomized trial comparing hormone replacement therapy (HRT) and HRT plus calcitriol in the treatment of postmenopausal osteoporosis with vertebral fractures: benefit of the combination on total body and hip density. Calcif Tissue Int. 2003;73(1):33-43. DES. [pmid: 14506952].
Guttuso T. Jr. Effective and clinically meaningful non-hormonal hot flash therapies. Maturitas. 2012. NRD.
Guttuso T. Effective and clinically meaningful non-hormonal hot flash therapies. Maturitas. 2012;72(1):6-12. NRD. [pmid: 22377187].
Hagen C., Christensen M. S., Christiansen C., Stocklund K. E., Transbol I. Effects of two years' estrogen-gestagen replacement on climacteric symptoms and gonadotropins in the early postmenopausal period. Acta Obstet Gynecol Scand. 1982;61(3):237-41. NOP. [pmid: 6812385].
von Hagens C., Schiller P., Godbillon B., Osburg J., Klose C., Limprecht R., Strowitzki T. Treating menopausal symptoms with a complex remedy or placebo: a randomized controlled trial. Climacteric. 2011. NRC.
Hailey D., Sampietro-Colom L., Marshall D., Rico R., Granados A., Asua J. The effectiveness of bone density measurement and associated treatments for prevention of fractures. An international collaborative review. Int J Technol Assess Health Care. 1998;14(2):237-54. NRO. [pmid: 9611900].
Haimov-Kochman R., Hochner-Celnikier D. Hot flashes revisited: pharmacological and herbal options for hot flashes management. What does the evidence tell us?. Acta Obstet Gynecol Scand. 2005;84(10):972-9. NRD. [pmid: 16167914].
Haines C., Harwood M. I. Gabapentin helpful for hot flushes in postmenopausal women. Journal of Family Practice. 2003;52(7):513-514. DUP. [pmid: 12841959].
Haines C. J., Xing S. M., Park K. H., Holinka C. F., Ausmanas M. K. Prevalence of menopausal symptoms in different ethnic groups of Asian women and responsiveness to therapy with three doses of conjugated estrogens/medroxyprogesterone acetate: the Pan-Asia Menopause (PAM) study. Maturitas. 2005;52(3-4):264-76. DUP. [pmid: 15921865].
Hall E., Frey B. N., Soares C. N. Non-hormonal treatment strategies for vasomotor symptoms: a critical review. Drugs. 2011;71(3):287-304. NRD. [pmid: 21319867].
Hardy R. Vasomotor menopausal symptoms and risk of coronary heart disease: A life course perspective. Menopause. 2011;18(2):127-128. NRQ. [pmid: 21135711].
Harris R. E., Namboodiri K. K., Wynder E. L. Breast cancer risk: effects of estrogen replacement therapy and body mass. J Natl Cancer Inst. 1992;84(20):1575-82. DES. [pmid: 1404451].
Hauselmann H. J., Rizzoli R. A comprehensive review of treatments for postmenopausal osteoporosis. Osteoporos Int. 2003;14(1):2-12. PTU. [pmid: 12577179].
Hayes L. P., Carroll D. G., Kelley K. W. Use of gabapentin for the management of natural or surgical menopausal hot flashes. Ann Pharmacother. 2011;45(3):388-94. NRD. [pmid: 21343402].
Hebert-Croteau N. A meta-analysis of hormone replacement therapy and colon cancer in women. Cancer Epidemiol Biomarkers Prev. 1998;7(8):653-9. PTU. [pmid: 9718216].
Heckbert S. R., Weiss N. S., Koepsell T. D., Lemaitre R. N., Smith N. L., Siscovick D. S., Lin D., Psaty B. M. Duration of estrogen replacement therapy in relation to the risk of incident myocardial infarction in postmenopausal women. Arch Intern Med. 1997;157(12):1330-6. DES. [pmid: 9201007].
Hedblad B., Merlo J., Manjer J., Engstrom G., Berglund G., Janzon L. Incidence of cardiovascular disease, cancer and death in postmenopausal women affirming use of hormone replacement therapy. Scand J Public Health. 2002;30(1):12-9. DES. [pmid: 11928828].
Hedelin M., Lof M., Olsson M., Adlercreutz H., Sandin S., Weiderpass E. Dietary phytoestrogens are not associated with risk of overall breast cancer but diets rich in coumestrol are inversely associated with risk of estrogen receptor and progesterone receptor negative breast tumors in Swedish women. J Nutr. 2008;138(5):938-45. NRD. [pmid: 18424605].
Heikkinen J. E., Vaheri R. T., Ahomaki S. M., Kainulainen P. M., Viitanen A. T., Timonen U. M. Optimizing continuous-combined hormone replacement therapy for postmenopausal women: a comparison of six different treatment regimens. Am J Obstet Gynecol. 2000;182(3):560-7. NRO. [pmid: 10739508].
Heikkinen J., Vaheri R., Timonen U. Long-term safety and tolerability of continuous-combined hormone therapy in postmenopausal women: results from a seven-year randomised comparison of low and standard doses. J Br Menopause Soc. 2004;10(3):95-102. DES. [pmid: 15494100].
Heikkinen J., Vaheri R., Timonen U. A 10-year follow-up of postmenopausal women on long-term continuous combined hormone replacement therapy: Update of safety and quality-of-life findings. J Br Menopause Soc. 2006;12(3):115-25. NRC. [pmid: 16953985].
Heinrich A. B., Wolf O. T. Investigating the effects of estradiol or estradiol/progesterone treatment on mood, depressive symptoms, menopausal symptoms and subjective sleep quality in older healthy hysterectomized women: a questionnaire study. Neuropsychobiology. 2005;52(1):17-23. NOP. [pmid: 15942259].
Hemminki E., McPherson K. Impact of postmenopausal hormone therapy on cardiovascular events and cancer: pooled data from clinical trials. BMJ. 1997;315(7101):149-53. PTU. [pmid: 9251544].
Hemminki E., Veerus P., Pisarev H., Hovi S. L., Topo P., Karro H. The effects of postmenopausal hormone therapy on social activity, partner relationship, and sexual life - experience from the EPHT trial. BMC Womens Health. 2009;9:16. NRO. [pmid: 19505307].
Hempling R. E., Wong C., Piver M. S., Natarajan N., Mettlin C. J. Hormone replacement therapy as a risk factor for epithelial ovarian cancer: results of a case-control study. Obstet Gynecol. 1997;89(6):1012-6. DES. [pmid: 9170483].
Henderson V. W., Lobo R. A. Hormone therapy and the risk of stroke: perspectives 10 years after the Women's Health Initiative trials. Climacteric. 2012;15(3):229-34. NCT. [pmid: 22612608].
Hendrix S. L. Hormone therapy: evolving concepts. Curr Opin Rheumatol. 2003;15(4):464-8. NCT. [pmid: 12819476].
Henrich J. B. The postmenopausal estrogen/breast cancer controversy. JAMA. 1992;268(14):1900-2. PTU. [pmid: 1404715].
Henrich J. B., Kornguth P. J., Viscoli C. M., Horwitz R. I. Postmenopausal estrogen use and invasive versus in situ breast cancer risk. J Clin Epidemiol. 1998;51(12):1277-83. DES. [pmid: 10086820].
Henry D., Robertson J., O'Connell D., Gillespie W. A systematic review of the skeletal effects of estrogen therapy in postmenopausal women. An I. assessment of the quality of randomized trials published between 1977 and 1995. Climacteric. 1998;1(2):92-111. PTU. [pmid: 11907921].
Herrington D. M. Effects of oestrogen on cardiovascular events in postmenopausal women. European Heart Journal. Supplement. 2001;3(M):M7-M11. NCT.
Herrinton L. J., Weiss N. S. Postmenopausal unopposed estrogens. Characteristics of use in relation to the risk of endometrial carcinoma. Ann Epidemiol. 1993;3(3):308-18. PTU. [pmid: 8275205].
Heyerick A., Vervarcke S., Depypere H., Bracke M., De Keukeleire D. A first prospective, randomized, double-blind, placebo-controlled study on the use of a standardized hop extract to alleviate menopausal discomforts. Maturitas. 2006;54(2):164-75. NOP. [pmid: 16321485].
Hildreth N. G., Kelsey J. L., LiVolsi V. A., Fischer D. B., Holford T. R., Mostow E. D., Schwartz P. E., White C. An epidemiologic study of epithelial carcinoma of the ovary. Am J Epidemiol. 1981;114(3):398-405. DES. [pmid: 7304575].
Hill D. A., Weiss N. S., Beresford S. A., Voigt L. F., Daling J. R., Stanford J. L., Self S. Continuous combined hormone replacement therapy and risk of endometrial cancer. Am J Obstet Gynecol. 2000;183(6):1456-61. DES. [pmid: 11120510].
Hirvonen E., Crona N., Wahlstrom T., Backstrom A. C. Effect of an estradiol gel with monthly or quarterly progestogen on menopausal symptoms and bleeding. Climacteric. 2000;3(4):262-70. NRD. [pmid: 11910586].
Hitchcock C. L., Prior J. C. Oral micronized progesterone for vasomotor symptoms-a placebo-controlled randomized trial in healthy postmenopausal women. Menopause. 2012;19(8):886-893. NRF. [pmid: 22453200].
Hlatky M. A., Boothroyd D., Vittinghoff E., Sharp P., Whooley M. A. Quality-of-life and depressive symptoms in postmenopausal women after receiving hormone therapy: results from the Heart and Estrogen/Progestin Replacement Study (HERS) trial. JAMA. 2002;287(5):591-7. NRP. [pmid: 11829697].
Hodis H. N., Mack W. J. Postmenopausal hormone therapy in clinical perspective. Menopause. 2007;14(5):944-57. NCT. [pmid: 17353803].
Hodis H. N., Mack W. J. A "window of opportunity": The reduction of coronary heart disease and total mortality with menopausal therapies is age- and time-dependent. Brain Research. 2011;1379:244-252. DES. [pmid: 20977895].
Hodis H. N., Collins P., Mack W. J., Schierbeck L. L. The timing hypothesis for coronary heart disease prevention with hormone therapy: past, present and future in perspective. Climacteric. 2012;15(3):217-28. NCT. [pmid: 22612607].
Hoffmeister M., Raum E., Krtschil A., Chang-Claude J., Brenner H. No evidence for variation in colorectal cancer risk associated with different types of postmenopausal hormone therapy. Clin Pharmacol Ther. 2009;86(4):416-24. DES. [pmid: 19606090].
Hogue C. W. Jr., Fucetola R., Hershey T., Nassief A., Birge S., Davila-Roman V. G., Barzilai B., Thomas B., Schechtman K. B., Freedland K. The role of postoperative neurocognitive dysfunction on quality of life for postmenopausal women 6 months after cardiac surgery. Anesth Analg. 2008;107(1):21-8. NRP. [pmid: 18635463].
Hoibraaten E., Qvigstad E., Arnesen H., Larsen S., Wickstrom E., Sandset P. M. Increased risk of recurrent venous thromboembolism during hormone replacement therapy--results of the randomized, double-blind, placebo-controlled estrogen in venous thromboembolism trial (EVTET). Thromb Haemost. 2000;84(6):961-7. DES. [pmid: 11154141].
Honkanen R. J., Honkanen K., Kroger H., Alhava E., Tuppurainen M., Saarikoski S. Risk factors for perimenopausal distal forearm fracture. Osteoporos Int. 2000;11(3):265-70. DES. [pmid: 10824244].
Honoris L., Budoff M. J. Postmenopausal Hormone Therapy: Does It Have a Role in Cardiovascular Prevention Today?. Current Cardiovascular Risk Reports. 2012;6(3):205-209. NCT.
Hormone replacement best for women < 60 years. South African Family Practice. 2005;47(1):20. DUP.
Hormone therapy. An update on risks and benefits. Mayo Clin Womens Healthsource. Suppl. 2009:1-8. NRD.
Horn-Ross P. L., John E. M., Canchola A. J., Stewart S. L., Lee M. M. Phytoestrogen intake and endometrial cancer risk. J Natl Cancer Inst. 2003;95(15):1158-64. NRD. [pmid: 12902445].
Horwitz R. I., Stewart K. R. Effect of clinical features on the association of estrogens and breast cancer. Am J Med. 1984;76(2):192-8. DES. [pmid: 6695946].
Howes L. G., Howes J. B., Knight D. C. Isoflavone therapy for menopausal flushes: a systematic review and meta-analysis. Maturitas. 2006;55(3):203-11. NRD. [pmid: 16675169].
Huang G., Basaria S., Travison T. G., Ho M. H., Davda M., Mazer N. A., Miciek R., Knapp P. E., Zhang A., Collins L., Ursino M., Appleman E., Dzekov C., Stroh H., Ouellette M., Rundell T., Baby M., Bhatia N. N., Khorram O., Friedman T., Storer T. W., Bhasin S. Testosterone dose-response relationships in hysterectomized women with or without oophorectomy: effects on sexual function, body composition, muscle performance and physical function in a randomized trial. Menopause. 2013. NOP.
Huang A., Yaffe K., Vittinghoff E., Kuppermann M., Addis I., Hanes V., Quan J., Grady D. The effect of ultralow-dose transdermal estradiol on sexual function in postmenopausal women. Am J Obstet Gynecol. 2008;198(3):265 e1-7. NRQ. [pmid: 18313446].
Huang A. J., Sawaya G. F., Vittinghoff E., Lin F., Grady D. Hot flushes, coronary heart disease, and hormone therapy in postmenopausal women. Menopause. 2009;16(4):639-43. DES. [pmid: 19325499].
Hubayter Z., Simon J. A. Testosterone therapy for sexual dysfunction in postmenopausal women. Climacteric. 2008;11(3):181-91. NRD. [pmid: 18568783].
Hudson T. Latest study shows red clover relieves hot flashes. Alternative and Complementary Therapies. 2003;9(3):137. NRD.
Hui C., Qi X., Qianyong Z., Xiaoli P., Jundong Z., Mantian M. Flavonoids, flavonoid subclasses and breast cancer risk: a meta-analysis of epidemiologic studies. PLoS One. 2013;8(1):e54318. NRQ. [pmid: 23349849].
Hulka B. S. Links between hormone replacement therapy and neoplasia. Fertil Steril. 1994;62(6 Suppl 2):168S-175S. NCT. [pmid: 7958013].
Hulley S., Grady D., Bush T., Furberg C., Herrington D., Riggs B., Vittinghoff E. Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group. JAMA. 1998;280(7):605-13. DES. [pmid: 9718051].
Humphrey L. L., Chan B. K., Sox H. C. Postmenopausal hormone replacement therapy and the primary prevention of cardiovascular disease. Ann Intern Med. 2002;137(4):273-84. PTU. [pmid: 12186518].
Humphrey L. L., Takano L. M. A., Chan S. B. K. Postmenopausal Hormone Replacement Therapy and Cardiovascular Disease. [Internet]. 2002. PTU.
Humphries K. H., McElhaney J. Hormone replacement therapy in the older adult. Geriatrics and Aging. 2006;9(2):114-118. NCT.
Hundrup Y. A., Hoidrup S., Ekholm O., Davidsen M., Obel E. B. Risk of low-energy hip, wrist, and upper arm fractures among current and previous users of hormone replacement therapy: The Danish Nurse Cohort Study. Eur J Epidemiol. 2004;19(12):1089-95. DES. [pmid: 15678788].
Hunt K., Vessey M., McPherson K., Coleman M. Long-term surveillance of mortality and cancer incidence in women receiving hormone replacement therapy. Br J Obstet Gynaecol. 1987;94(7):620-35. DES. [pmid: 3620411].
Huntley A. L. Compounded or confused? Bioidentical hormones and menopausal health. Menopause Int. 2011;17(1):16-8. NRQ. [pmid: 21427420].
Huntley A. L., Ernst E. Soy for the treatment of perimenopausal symptoms--a systematic review. Maturitas. 2004;47(1):1-9. NRD. [pmid: 14706760].
Huntley A. L., Ernst E. A systematic review of herbal medicinal products for the treatment of menopausal symptoms. Menopause. 2003;10(5):465-76. NRD. [pmid: 14501609].
Hutchinson T. A., Polansky S. M., Feinstein A. R. Post-menopausal oestrogens protect against fractures of hip and distal radius. A case-control study. Lancet. 1979;2(8145):705-9. DES. [pmid: 90802].
Imai A., Matsunami K., Takagi H., Ichigo S. New generation nonhormonal management for hot flashes. Gynecol Endocrinol. 2013;29(1):63-6. NRD. [pmid: 22809093].
SSRIs ineffective for hot flashes. South African Family Practice. 2005;47(3):17. DUP.
Ishida Y., Kawai S. Comparative efficacy of hormone replacement therapy, etidronate, calcitonin, alfacalcidol, and vitamin K in postmenopausal women with osteoporosis: The Yamaguchi Osteoporosis Prevention Study. Am J Med. 2004;117(8):549-55. DES. [pmid: 15465502].
Ishiwata N., Melby M. K., Mizuno S., Watanabe S. New equol supplement for relieving menopausal symptoms: randomized, placebo-controlled trial of Japanese women. Menopause. 2009;16(1):141-8. NOP. [pmid: 19131846].
Iwamoto J., Sato Y., Takeda T., Matsumoto H. High-dose vitamin K supplementation reduces fracture incidence in postmenopausal women: a review of the literature. Nutr Res. 2009;29(4):221-8. NRQ. [pmid: 19410972].
Jaakkola S., Lyytinen H. K., Dyba T., Ylikorkala O., Pukkala E. Endometrial cancer associated with various forms of postmenopausal hormone therapy: a case control study. Int J Cancer. 2011;128(7):1644-51. DES. [pmid: 21280035].
Jaakkola S., Lyytinen H., Pukkala E., Ylikorkala O. Endometrial cancer in postmenopausal women using estradiol-progestin therapy. Obstet Gynecol. 2009;114(6):1197-204. DES. [pmid: 19935019].
Jackson R. D., Wactawski-Wende J., LaCroix A. Z., Pettinger M., Yood R. A., Watts N. B., Robbins J. A., Lewis C. E., Beresford S. A., Ko M. G., Naughton M. J., Satterfield S., Bassford T. Effects of conjugated equine estrogen on risk of fractures and BMD in postmenopausal women with hysterectomy: results from the women's health initiative randomized trial. J Bone Miner Res. 2006;21(6):817-28. DES. [pmid: 16753012].
Jacobs A., Wegewitz U., Sommerfeld C., Grossklaus R., Lampen A. Efficacy of isoflavones in relieving vasomotor menopausal symptoms - A systematic review. Mol Nutr Food Res. 2009;53(9):1084-97. NRD. [pmid: 19653225].
Jaisamrarn U., Triratanachat S., Chaikittisilpa S., Grob P., Prasauskas V., Taechakraichana N. Ultra-low-dose estriol and lactobacilli in the local treatment of postmenopausal vaginal atrophy. Climacteric. 2013;16(3):347-355. NRO. [pmid: 23347400].
Jaschevatzky O. E., Anderman S., Shalit A., Kampf D., Grunstein S. The treatment of postmenopausal syndrome by monthly oral doses of quinestrol. Acta Obstet Gynecol Scand. 1979;58(2):175-8. NRO. [pmid: 452871].
Jenks B. H., Iwashita S., Nakagawa Y., Ragland K., Lee J., Carson W. H., Ueno T., Uchiyama S. A pilot study on the effects of S-equol compared to soy isoflavones on menopausal hot flash frequency. J Womens Health (Larchmt). 2012;21(6):674-82. NRF. [pmid: 22409590].
Jensen P. B., Jensen J., Riis B. J., Rodbro P., Strom V., Christiansen C. Climacteric symptoms after oral and percutaneous hormone replacement therapy. Maturitas. 1987;9(3):207-15. NOP. [pmid: 2963205].
Jick H., Derby L. E., Myers M. W., Vasilakis C., Newton K. M. Risk of hospital admission for idiopathic venous thromboembolism among users of postmenopausal oestrogens. Lancet. 1996;348(9033):981-3. DES. [pmid: 8855853].
Jick S. S., Hagberg K. W., Kaye J. A., Jick H. Postmenopausal estrogen-containing hormone therapy and the risk of breast cancer. Obstet Gynecol. 2009;113(1):74-80. DES. [pmid: 19104362].
Joffe M. M., Byrne C., Colditz G. A. Postmenopausal hormone use, screening, and breast cancer: characterization and control of a bias. Epidemiology. 2001;12(4):429-38. DES. [pmid: 11416781].
Johannisson E., Holinka C. F., Arrenbrecht S. Transdermal sequential and continuous hormone replacement regimens with estradiol and norethisterone acetate in postmenopausal women: effects on the endometrium. Int J Fertil Womens Med. Suppl 2. 1997;42:388-98. DES. [pmid: 9397386].
Johansen O. E., Qvigstad E. Rationale for low-dose systemic hormone replacement therapy and review of estradiol 0.5 mg/NETA 0.1 mg. Adv Ther. 2008;25(6):525-51. NCT. [pmid: 18568306].
Johnson E. D., Carroll D. G. Venlafaxine and desvenlafaxine in the management of menopausal hot flashes. Pharmacy Practice. 2011;9(3):117-122. NRD. [pmid: 24367464].
Johnson E. D., Carroll D. G. Venlafaxine and desvenlafaxine in the management of menopausal hot flashes. Pharmacy Practice. 2011;9(3):117-122. NRD. [pmid: 24367464].
Josse R. G. Prevention and management of osteoporosis: consensus statements from the Scientific Advisory Board of the Osteoporosis Society of Canada. 3. Effects of ovarian hormone therapy on skeletal and extraskeletal tissues in women. CMAJ. 1996;155(7):929-34. NCT. [pmid: 8837542].
Jou H. J., Ling P. Y., Wu S. C. Comparison of 70 mg and 35 mg isoflavone soya supplement for menopause symptoms. Int J Gynaecol Obstet. 2005;90(2):159-60. NOP. [pmid: 15913629].
Kagan R., Sweeney M. Effect of gabapentin extended release on sleep parameters in post- menopausal women. Menopause. 2012;19(12):1373. DUP.
Kalogirou D., Antoniou G., Karakitsos P., Kalogirou O., Antoniou D., Giannikos L. A comparative study of the effects of an estradiol-releasing vaginal ring combined with an oral gestagen versus transdermal estrogen combined with a levonorgestrel-releasing IUD: clinical findings and endometrial response. Int J Fertil Menopausal Stud. 1996;41(6):522-7. NRO. [pmid: 9010746].
Kapil S., Lawal K. T. O., Locklear T. D., Mahady G. B. Black cohosh for menopause: Safety and efficacy issues and future perspectives. Drug Information Journal. 2011;45(1):37-44. NRD.
Kaplan R. C., Heckbert S. R., Weiss N. S., Wahl P. W., Smith N. L., Newton K. M., Psaty B. M. Postmenopausal estrogens and risk of myocardial infarction in diabetic women. Diabetes Care. 1998;21(7):1117-21. DES. [pmid: 9653605].
Karlberg J., Mattsson L. A., Wiklund I. A quality of life perspective on who benefits from estradiol replacement therapy. Acta Obstet Gynecol Scand. 1995;74(5):367-72. DUP. [pmid: 7778430].
Kase N. G. Impact of hormone therapy for women aged 35 to 65 years, from contraception to hormone replacement. Gend Med. Suppl 1. 2009;6:37-59. NRO. [pmid: 19318218].
Kaszkin-Bettag M., Ventskovskiy B. M., Kravchenko A., Rettenberger R., Richardson A., Heger P. W., Heger M. The special extract ERr 731 of the roots of Rheum rhaponticum decreases anxiety and improves health state and general well-being in perimenopausal women. Menopause. 2007;14(2):270-83. DUP. [pmid: 17213754].
Kaufman D. W., Kelly J. P., Welch W. R., Rosenberg L., Stolley P. D., Warshauer M. E., Lewis J., Woodruff J., Shapiro S. Noncontraceptive estrogen use and epithelial ovarian cancer. Am J Epidemiol. 1989;130(6):1142-51. DES. [pmid: 2589307].
Kaufman D. W., Palmer J. R., de Mouzon J., Rosenberg L., Stolley P. D., Warshauer M. E., Zauber A. G., Shapiro S. Estrogen replacement therapy and the risk of breast cancer: results from the case-control surveillance study. Am J Epidemiol. 1991;134(12):1375-85. discussion 1396-401. DES. [pmid: 1663700].
Kaunitz A., Sanacora G., Bhaskar S., Lippman J. Safety and efficacy of low-dose mesylate salt of paroxetine (LDMP) for the treatment of vasomotor symptoms (VMS) associated with menopause: A 12-week, randomized, placebo-controlled phase 3 study. Menopause. 2012;19(12):1389. DUP.
Kelley K. W., Carroll D. G. Evaluating the evidence for over-the-counter alternatives for relief of hot flashes in menopausal women. J Am Pharm Assoc (2003). 2010;50(5):e106-15. NRD. [pmid: 20833608].
Kelsey J. L., Fischer D. B., Holford T. R., LiVoisi V. A., Mostow E. D., Goldenberg I. S., White C. Exogenous estrogens and other factors in the epidemiology of breast cancer. J Natl Cancer Inst. 1981;67(2):327-33. DES. [pmid: 6943372].
Kelsey J. L., Keegan T. H., Prill M. M., Quesenberry C. P. Jr., Sidney S. Risk factors for fracture of the shafts of the tibia and fibula in older individuals. Osteoporos Int. 2006;17(1):143-9. DES. [pmid: 16088362].
Kelsey J. L., LiVolsi V. A., Holford T. R., Fischer D. B., Mostow E. D., Schwartz P. E., O'Connor T., White C. A case-control study of cancer of the endometrium. Am J Epidemiol. 1982;116(2):333-42. DES. [pmid: 7114042].
Khoo S. K., Chick P. Sex steroid hormones and breast cancer: is there a link with oral contraceptives and hormone replacement therapy?. Med J Aust. 1992;156(2):124-32. PTU. [pmid: 1736053].
Khoo S. K., Coglan M., Battistutta D., Tippett V., Raphael B. Hormonal treatment and psychological function during the menopausal transition: an evaluation of the effects of conjugated estrogens/cyclic medroxyprogesterone acetate. Climacteric. 1998;1(1):55-62. NRP. [pmid: 11907928].
Kiel D. P., Felson D. T., Anderson J. J., Wilson P. W., Moskowitz M. A. Hip fracture and the use of estrogens in postmenopausal women. The Framingham Study. N Engl J Med. 1987;317(19):1169-74. DES. [pmid: 3657888].
Kim M. S., Lim H. J., Yang H. J., Lee M. S., Shin B. C., Ernst E. Ginseng for managing menopause symptoms: a systematic review of randomized clinical trials. J Ginseng Res. 2013;37(1):30-6. NRD. [pmid: 23717154].
Kim S. Y., Seo S. K., Choi Y. M., Jeon Y. E., Lim K. J., Cho S., Choi Y. S., Lee B. S. Effects of red ginseng supplementation on menopausal symptoms and cardiovascular risk factors in postmenopausal women: a double-blind randomized controlled trial. Menopause. 2012;19(4):461-6. DUP. [pmid: 22027944].
Kingsberg S. A., Simon J. A., Goldstein I. The current outlook for testosterone in the management of hypoactive sexual desire disorder in postmenopausal women. J Sex Med. Suppl 4. 2008;5:182-93. quiz 193. NRD. [pmid: 18783534].
Kingsberg S., Shifren J., Wekselman K., Rodenberg C., Koochaki P., Derogatis L. Evaluation of the clinical relevance of benefits associated with transdermal testosterone treatment in postmenopausal women with hypoactive sexual desire disorder. J Sex Med. 2007;4(4 Pt 1):1001-8. DUP. [pmid: 17627745].
Kirsh V., Kreiger N. Estrogen and estrogen-progestin replacement therapy and risk of postmenopausal breast cancer in Canada. Cancer Causes Control. 2002;13(6):583-90. DES. [pmid: 12195648].
Kittner S. J., Bousser M. G. Post-menopausal hormone replacement therapy and stroke risk. Cephalalgia. 2000;20(3):208-13. NCT. [pmid: 10997775].
Knight D. C., Eden J. A. A review of the clinical effects of phytoestrogens. Obstet Gynecol. 1996;87(5 Pt 2):897-904. NRD. [pmid: 8677131].
Kocjan T., Prelevic G. M. Hormone replacement therapy update: who should we be prescribing this to now?. Curr Opin Obstet Gynecol. 2003;15(6):459-64. NCT. [pmid: 14624210].
Koninckx P. R., Lauweryns J. M., Cornillie F. J. Endometrial effects during hormone replacement therapy with a sequential oestradiol valerate/cyproterone acetate preparation. Maturitas. 1993;16(2):97-110. NOP. [pmid: 8387151].
Kotsopoulos J., Lubinski J., Neuhausen S. L., Lynch H. T., Rosen B., Ainsworth P., Moller P., Ghadirian P., Isaacs C., Karlan B., Sun P., Narod S. A. Hormone replacement therapy and the risk of ovarian cancer in BRCA1 and BRCA2 mutation carriers. Gynecol Oncol. 2006;100(1):83-8. DES. [pmid: 16137751].
Kotz K., Alexander J. L., Dennerstein L. Estrogen and androgen hormone therapy and well-being in surgically postmenopausal women. J Womens Health (Larchmt). 2006;15(8):898-908. NRD. [pmid: 17087613].
Krebs E. E., Ensrud K. E., MacDonald R., Wilt T. J. Phytoestrogens for treatment of menopausal symptoms: a systematic review. Obstet Gynecol. 2004;104(4):824-36. NRD. [pmid: 15458907].
Kreiger N., Kelsey J. L., Holford T. R., O'Connor T. An epidemiologic study of hip fracture in postmenopausal women. Am J Epidemiol. 1982;116(1):141-8. DES. [pmid: 7102649].
Krieger N. Hormone therapy and the rise and perhaps fall of US breast cancer incidence rates: critical reflections. Int J Epidemiol. 2008;37(3):627-37. NRD. [pmid: 18375445].
Kristensen S. R., Abrahamsen B., Madsen J. S., Gram J., Rejnmark L., Rud B., Jespersen J. Venous thrombosis is not increased in younger women on genuine oestrogen postmenopausal hormonal replacement therapy: results from the Danish Osteoporosis Prevention Study (DOPS). Thromb Haemost. 2006;95(5):915-6. DES. [pmid: 16676096].
Kritz-Silverstein D., Von Muhlen D., Barrett-Connor E., Bressel M. A. Isoflavones and cognitive function in older women: the SOy and Postmenopausal Health In Aging (SOPHIA) Study. Menopause. 2003;10(3):196-202. NRO. [pmid: 12792289].
Kronenberg F., Fugh-Berman A. Complementary and alternative medicine for menopausal symptoms: a review of randomized, controlled trials. Ann Intern Med. 2002;137(10):805-13. NRD. [pmid: 12435217].
Krychman M. L. Vaginal estrogens for the treatment of dyspareunia. Journal of Sexual Medicine. 2011;8(3):666-674. NRD. [pmid: 21091878].
Krychman M. L. Vaginal estrogens for the treatment of dyspareunia. Journal of Sexual Medicine. 2011;8(3):666-674. NRD. [pmid: 21091878].
Kupfersztain C., Rotem C., Fagot R., Kaplan B. The immediate effect of natural plant extract, Angelica sinensis and Matricaria chamomilla (Climex) for the treatment of hot flushes during menopause. A preliminary report. Clin Exp Obstet Gynecol. 2003;30(4):203-6. NOP. [pmid: 14664413].
Kurzer M. S. Soy consumption for reduction of menopausal symptoms. Inflammopharmacology. 2008;16(5):227-9. NRD. [pmid: 18815739].
LaCroix A. Z. Estrogen with and without progestin: benefits and risks of short-term use. Am J Med. Suppl 12B. 2005;118:79-87. NCT. [pmid: 16414331].
LaCroix A. Z., Chlebowski R. T., Manson J. E., Aragaki A. K., Johnson K. C., Martin L., Margolis K. L., Stefanick M. L., Brzyski R., Curb J. D., Howard B. V., Lewis C. E., Wactawski-Wende J. Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy: a randomized controlled trial. JAMA. 2011;305(13):1305-14. DES. [pmid: 21467283].
La Vecchia C. Sex hormones and cardiovascular risk. Hum Reprod. 1992;7(2):162-7. NCT. [pmid: 1577926].
La Vecchia C., Franceschi S. Reproductive factors and colorectal cancer. Cancer Causes Control. 1991;2(3):193-200. NRQ. [pmid: 1873449].
La Vecchia C., Brinton L. A., McTiernan A. Menopause, hormone replacement therapy and cancer. Maturitas. 2001;39(2):97-115. NCT. [pmid: 11514109].
La Vecchia C., Franceschi S., Decarli A., Gallus G., Tognoni G. Risk factors for endometrial cancer at different ages. J Natl Cancer Inst. 1984;73(3):667-71. DES. [pmid: 6590913].
La Vecchia C., Franceschi S., Gallus G., Decarli A., Colombo E., Mangioni C., Tognoni G. Oestrogens and obesity as risk factors for endometrial cancer in Italy. Int J Epidemiol. 1982;11(2):120-6. DES. [pmid: 7095961].
La Vecchia C., Gallus S., Fernandez E. Hormone replacement therapy and colorectal cancer: an update. J Br Menopause Soc. 2005;11(4):166-72. PTU. [pmid: 16354462].
Laakmann E., Grajecki D., Doege K., zu Eulenburg C., Buhling K. J. Efficacy of Cimicifuga racemosa, Hypericum perforatum and Agnus castus in the treatment of climacteric complaints: a systematic review. Gynecol Endocrinol. 2012;28(9):703-9. NRD. [pmid: 22385322].
Labrie F., Archer D., Bouchard C., Fortier M., Cusan L., Gomez J. L., Girard G., Baron M., Ayotte N., Moreau M., Dube R., Cote I., Labrie C., Lavoie L., Berger L., Martel C., Balser J. High internal consistency and efficacy of intravaginal DHEA for vaginal atrophy. Gynecol Endocrinol. 2010;26(7):524-32. NRO. [pmid: 20459349].
Labrie F., Archer D., Bouchard C., Fortier M., Cusan L., Gomez J. L., Girard G., Baron M., Ayotte N., Moreau M., Dube R., Cote I., Labrie C., Lavoie L., Berger L., Gilbert L., Martel C., Balser J. Intravaginal dehydroepiandrosterone (Prasterone), a physiological and highly efficient treatment of vaginal atrophy. Menopause. 2009;16(5):907-22. DUP. [pmid: 19436225].
Labrie F., Archer D., Bouchard C., Fortier M., Cusan L., Gomez J. L., Girard G., Baron M., Ayotte N., Moreau M., Dube R., Cote I., Labrie C., Lavoie L., Berube R., Belanger P., Berger L., Gilbert L., Martel C., Balser J. Serum steroid levels during 12-week intravaginal dehydroepiandrosterone administration. Menopause. 2009;16(5):897-906. NRO. [pmid: 19436226].
Labrie F., Archer D. F., Bouchard C., Fortier M., Cusan L., Gomez J. L., Girard G., Baron M., Ayotte N., Moreau M., Dube R., Cote I., Labrie C., Lavoie L., Berger L., Gilbert L., Martel C., Balser J. Intravaginal dehydroepiandrosterone (prasterone), a highly efficient treatment of dyspareunia. Climacteric. 2011;14(2):282-8. NRO. [pmid: 21244215].
Lacey J. V. Jr., Brinton L. A., Lubin J. H., Sherman M. E., Schatzkin A., Schairer C. Endometrial carcinoma risks among menopausal estrogen plus progestin and unopposed estrogen users in a cohort of postmenopausal women. Cancer Epidemiol Biomarkers Prev. 2005;14(7):1724-31. DES. [pmid: 16030108].
Lacey J. V. Jr., Brinton L. A., Leitzmann M. F., Mouw T., Hollenbeck A., Schatzkin A., Hartge P. Menopausal hormone therapy and ovarian cancer risk in the National Institutes of Health-AARP Diet and Health Study Cohort. J Natl Cancer Inst. 2006;98(19):1397-405. DES. [pmid: 17018786].
Lacroix A. Z., Freeman E. W., Larson J., Carpenter J. S., Joffe H., Reed S. D., Newton K. M., Seguin R. A., Sternfeld B., Cohen L., Ensrud K. E. Effects of escitalopram on menopause-specific quality of life and pain in healthy menopausal women with hot flashes: A randomized controlled trial. Maturitas. 2012;73(4):361-368. DUP. [pmid: 23031421].
Lafferty F. W., Fiske M. E. Postmenopausal estrogen replacement: a long-term cohort study. Am J Med. 1994;97(1):66-77. DES. [pmid: 8030659].
Lahmann P. H., Hoffmann K., Allen N., van Gils C. H., Khaw K. T., Tehard B., Berrino F., Tjonneland A., Bigaard J., Olsen A., Overvad K., Clavel-Chapelon F., Nagel G., Boeing H., Trichopoulos D., Economou G., Bellos G., Palli D., Tumino R., Panico S., Sacerdote C., Krogh V., Peeters P. H., Bueno-de-Mesquita H. B., Lund E., Ardanaz E., Amiano P., Pera G., Quiros J. R., Martinez C., Tormo M. J., Wirfalt E., Berglund G., Hallmans G., Key T. J., Reeves G., Bingham S., Norat T., Biessy C., Kaaks R., Riboli E. Body size and breast cancer risk: findings from the European Prospective Investigation into Cancer And Nutrition (EPIC). Int J Cancer. 2004;111(5):762-71. DES. [pmid: 15252848].
Laliberte F., Dea K., Duh M. S., Kahler K. H., Rolli M., Lefebvre P. Does the route of administration for estrogen hormone therapy impact the risk of venous thromboembolism? Estradiol transdermal system versus oral estrogen-only hormone therapy. Menopause. 2011;18(10):1052-9. DES. [pmid: 21775912].
Le Gal G., Kovacs M. J., Carrier M., Do K., Kahn S. R., Wells P. S., Anderson D. A., Chagnon I., Solymoss S., Crowther M., Righini M., Lacut K., White R. H., Vickars L., Rodger M. Risk of recurrent venous thromboembolism after a first oestrogen-associated episode. Data from the REVERSE cohort study. Thromb Haemost. 2010;104(3):498-503. DES. [pmid: 20539910].
Leach M. J., Moore V. Black cohosh (Cimicifuga spp.) for menopausal symptoms. Cochrane Database Syst Rev. 2012;9:CD007244. NRD. [pmid: 22972105].
Leach M. J., Moore V. Black cohosh (Cimicifuga spp.) for menopausal symptoms. Cochrane Database of Systematic Reviews. 2008;(3). NRD.
de Lecinana M. A., Egido J. A., Fernandez C., Martinez-Vila E., Santos S., Morales A., Martinez E., Pareja A., Alvarez-Sabin J., Casado I. Risk of ischemic stroke and lifetime estrogen exposure. Neurology. 2007;68(1):33-8. DES. [pmid: 17200489].
Lee M. S., Shin B. C., Yang E. J., Lim H. J., Ernst E. Maca (Lepidium meyenii) for treatment of menopausal symptoms: A systematic review. Maturitas. 2011;70(3):227-33. NRD. [pmid: 21840656].
Lee S. A., Ross R. K., Pike M. C. An overview of menopausal oestrogen-progestin hormone therapy and breast cancer risk. Br J Cancer. 2005;92(11):2049-58. PTU. [pmid: 15900297].
Lee S., Kolonel L., Wilkens L., Wan P., Henderson B., Pike M. Postmenopausal hormone therapy and breast cancer risk: the Multiethnic Cohort. Int J Cancer. 2006;118(5):1285-91. DES. [pmid: 16170777].
Lee Y., Dharmala K., Lee C. H. An intelligent data mining model approach for adverse effects of hormone replacement therapy. Methods Inf Med. 2007;46(1):5-18. NRQ. [pmid: 17224975].
van Leeuwen F. E. Epidemiologic aspects of exogenous progestagens in relation to their role in pathogenesis of human breast cancer. Acta Endocrinol (Copenh). Suppl 1. 1991;125:13-26. NCT. [pmid: 1801500].
Lemaitre R. N., Weiss N. S., Smith N. L., Psaty B. M., Lumley T., Larson E. B., Heckbert S. R. Esterified estrogen and conjugated equine estrogen and the risk of incident myocardial infarction and stroke. Arch Intern Med. 2006;166(4):399-404. DES. [pmid: 16505258].
Lemaitre R. N., Heckbert S. R., Psaty B. M., Smith N. L., Kaplan R. C., Longstreth W. T. Jr. Hormone replacement therapy and associated risk of stroke in postmenopausal women. Arch Intern Med. 2002;162(17):1954-60. DES. [pmid: 12230417].
Lethaby A., Marjoribanks J., Kronenberg F., Roberts H., Eden J., Brown J. Phytoestrogens for menopausal vasomotor symptoms. Cochrane Database Syst Rev. 2013;12:CD001395. NRD. [pmid: 24323914].
Lethaby A. E., Brown J., Marjoribanks J., Kronenberg F., Roberts H., Eden J. Phytoestrogens for vasomotor menopausal symptoms. Cochrane Database Syst Rev. 2007;(4):CD001395. NRD. [pmid: 17943751].
Lethaby A., Suckling J., Barlow D., Farquhar C. M., Jepson R. G., Roberts H. Hormone replacement therapy in postmenopausal women: endometrial hyperplasia and irregular bleeding. Cochrane Database Syst Rev. 2004;(3):CD000402. PTU. [pmid: 15266429].
Leung P. C., Cheng K. F., Chan Y. H. An innovative herbal product for the prevention of osteoporosis. Chin J Integr Med. 2011;17(10):744-9. NRO. [pmid: 22101698].
Levi F., Lucchini F., Pasche C., La Vecchia C. Oral contraceptives, menopausal hormone replacement treatment and breast cancer risk. Eur J Cancer Prev. 1996;5(4):259-66. DES. [pmid: 8894563].
Levine D. W., Dailey M. E., Rockhill B., Tipping D., Naughton M. J., Shumaker S. A. Validation of the Women's Health Initiative Insomnia Rating Scale in a multicenter controlled clinical trial. Psychosom Med. 2005;67(1):98-104. NRQ. [pmid: 15673630].
Li C. I. Postmenopausal hormone therapy and the risk of breast cancer: the view of an epidemiologist. Maturitas. 2004;49(1):44-50. NCT. [pmid: 15351095].
Li C. I., Malone K. E., Daling J. R. Interactions between body mass index and hormone therapy and postmenopausal breast cancer risk (United States). Cancer Causes Control. 2006;17(5):695-703. DES. [pmid: 16633917].
Li C. I., Malone K. E., Porter P. L., Lawton T. J., Voigt L. F., Cushing-Haugen K. L., Lin M. G., Yuan X., Daling J. R. Relationship between menopausal hormone therapy and risk of ductal, lobular, and ductal-lobular breast carcinomas. Cancer Epidemiol Biomarkers Prev. 2008;17(1):43-50. DES. [pmid: 18199710].
Li C. I., Weiss N. S., Stanford J. L., Daling J. R. Hormone replacement therapy in relation to risk of lobular and ductal breast carcinoma in middle-aged women. Cancer. 2000;88(11):2570-7. DES. [pmid: 10861435].
Li C., Engstrom G., Hedblad B., Berglund G., Janzon L. Risk of stroke and hormone replacement therapy. A prospective cohort study. Maturitas. 2006;54(1):11-8. DES. [pmid: 16321486].
Li R., Gilliland F. D., Baumgartner K., Samet J. Hormone replacement therapy and breast carcinoma risk in Hispanic and non-Hispanic women. Cancer. 2002;95(5):960-8. DES. [pmid: 12209678].
Liao E. Y., Luo X. H., Deng X. G., Wu X. P., Liao H. J., Wang P. F., Mao J. P., Zhu X. P., Huang G., Wei Q. Y. The effect of low dose nylestriol-levonorgestrel replacement therapy on bone mineral density in women with postmenopausal osteoporosis. Endocr Res. 2003;29(2):217-26. DES. [pmid: 12856809].
de Lignieres B., de Vathaire F., Fournier S., Urbinelli R., Allaert F., Le M. G., Kuttenn F. Combined hormone replacement therapy and risk of breast cancer in a French cohort study of 3175 women. Climacteric. 2002;5(4):332-40. DES. [pmid: 12626212].
Limouzin-Lamothe M. A., Mairon N., Joyce C. R., Le Gal M. Quality of life after the menopause: influence of hormonal replacement therapy. Am J Obstet Gynecol. 1994;170(2):618-24. NRC. [pmid: 7509570].
Limpaphayom K. K., Bunyavejchevin S. Clinical effects of 17 beta-estradiol and norethisterone acetate in postmenopausal Thai women. J Med Assoc Thai. 2000;83(4):407-16. NOP. [pmid: 10808701].
Lin K. J., Cheung W. Y., Lai J. Y., Giovannucci E. L. The effect of estrogen vs. combined estrogen-progestogen therapy on the risk of colorectal cancer. Int J Cancer. 2012;130(2):419-30. PTU. [pmid: 21365647].
Lin T. J., So-Bosita J. L., Brar H. K., Roblete B. V. Clinical and cytologic responses of postmenopausal women to estrogen. Obstet Gynecol. 1973;41(1):97-107. DES. [pmid: 4345382].
Lindh-Astrand L., Bixo M., Hirschberg A. L., Sundstrom-Poromaa I., Hammar M. A randomized controlled study of taper-down or abrupt discontinuation of hormone therapy in women treated for vasomotor symptoms. Menopause. 2010;17(1):72-9. NRQ. [pmid: 19675505].
Lindsay R., Hart D. M. Failure of response of menopausal vasomotor symptoms to clonidine. Maturitas. 1978;1(1):21-5. NOP. [pmid: 386045].
Lipovac M., Chedraui P., Gruenhut C., Gocan A., Kurz C., Neuber B., Imhof M. The effect of red clover isoflavone supplementation over vasomotor and menopausal symptoms in postmenopausal women. Gynecol Endocrinol. 2012;28(3):203-7. DUP. [pmid: 21870906].
Lipworth L., Katsouyanni K., Stuver S., Samoli E., Hankinson S. E., Trichopoulos D. Oral contraceptives, menopausal estrogens, and the risk of breast cancer: a case-control study in Greece. Int J Cancer. 1995;62(5):548-51. DES. [pmid: 7665225].
Liu J. Does Dang Gui Buxue Tang improve moderate to severe menopausal symptoms and quality of life in post-menopausal women?. Focus on Alternative and Complementary Therapies. 2013;18:140-141. NOP.
Liu B., Beral V., Balkwill A., Green J., Sweetland S., Reeves G. Gallbladder disease and use of transdermal versus oral hormone replacement therapy in postmenopausal women: prospective cohort study. BMJ. 2008;337:a386. DES. [pmid: 18617493].
Liu J. H. Therapeutic effects of progestins, androgens, and tibolone for menopausal symptoms. Am J Med. Suppl 12B. 2005;118:88-92. NRD. [pmid: 16414332].
Liu J. H., Muse K. N. The effects of progestins on bone density and bone metabolism in postmenopausal women: a randomized controlled trial. Am J Obstet Gynecol. 2005;192(4):1316-23. discussion 1323-4. DES. [pmid: 15846228].
Liu J. H., Reape K. Z., Hait H. I. Synthetic conjugated estrogens-B and postmenopausal nocturnal vasomotor symptoms: a randomized controlled trial. Obstet Gynecol. 2012;119(1):78-84. DUP. [pmid: 22183214].
Lobo R. A. Evaluation of cardiovascular event rates with hormone therapy in healthy, early postmenopausal women: results from 2 large clinical trials. Arch Intern Med. 2004;164(5):482-4. DES. [pmid: 15006823].
Lobo R. A. Where are we 10 years after the women's health initiative?. Journal of Clinical Endocrinology and Metabolism. 2013;98(5):1771-1780. NCT. [pmid: 23493433].
Lobo R. A. The risk of stroke in postmenopausal women receiving hormonal therapy. Climacteric. Suppl 1. 2009;12:81-5. PTU. [pmid: 19811248].
Lobo R. A., Belisle S., Creasman W. T., Frankel N, R., Goodman N. E., Hall J. E., Ivey S. L., Kingsberg S., Langer R., Lehman R., McArthur D. B., Montgomery-Rice V., Notelovitz M., Packin G. S., Rebar R. W., Rousseau M., Schenken R. S., Schneider D. L., Sherif K., Wysocki S. Should symptomatic menopausal women be offered hormone therapy?. MedGenMed Medscape General Medicine. 2006;8(2). NCT.
Lochner D. M., Brubaker K. L. Incidence of malignancy in hormone therapy users with indeterminate calcifications on mammogram. Am J Obstet Gynecol. 2006;194(1):82-5. DES. [pmid: 16389013].
Lokkegaard E., Nielsen A., Nielsen L., Lidegaard O. Risk of stroke with postmenopausal hormone therapy. A National cohort study. Acta Obstetricia et Gynecologica Scandinavica. 2012;91:106-107. NRD.
Lokkegaard E., Jovanovic Z., Heitmann B. L., Keiding N., Ottesen B., Hundrup Y. A., Obel E. B., Pedersen A. T. Increased risk of stroke in hypertensive women using hormone therapy: analyses based on the Danish Nurse Study. Arch Neurol. 2003;60(10):1379-84. DES. [pmid: 14568807].
London S. HRT doesn't worsen breast cancer risk following oophorectomy. Oncology Report. 2011;(JULY-AUGUST):13. NCT.
Longnecker M. P., Bernstein L., Paganini-Hill A., Enger S. M., Ross R. K. Risk factors for in situ breast cancer. Cancer Epidemiol Biomarkers Prev. 1996;5(12):961-5. DES. [pmid: 8959317].
Longstreth W. T., Nelson L. M., Koepsell T. D., van Belle G. Subarachnoid hemorrhage and hormonal factors in women. A population-based case-control study. Ann Intern Med. 1994;121(3):168-73. DES. [pmid: 8017743].
Lopes P., Merkus H. M., Nauman J., Bruschi F., Foidart J. M., Calaf J. Randomized comparison of intranasal and transdermal estradiol. Obstet Gynecol. 2000;96(6):906-12. DUP. [pmid: 11084176].
Loprinzi C. L., Barton D. L., Sloan J. A., Novotny P. J., Wolf S. Newer antidepressants for hot flashes--should their efficacy still be up for debate?. Menopause. 2009;16(1):184-7. NRD. [pmid: 18725865].
Loprinzi C. L., Qin R., Balcueva E. P., Flynn K. A., Rowland K. M. Jr., Graham D. L., Erwin N. K., Dakhil S. R., Jurgens D. J., Burger K. N. Phase III, randomized, double-blind, placebo-controlled evaluation of pregabalin for alleviating hot flashes, N07C1. J Clin Oncol. 2010;28(4):641-7. NRP. [pmid: 19901102].
Loprinzi C. L., Stearns V., Barton D. Centrally active nonhormonal hot flash therapies. Am J Med. Suppl 12B. 2005;118:118-23. NRD. [pmid: 16414336].
Low Dog T. Menopause: a review of botanical dietary supplements. Am J Med. Suppl 12B. 2005;118:98-108. NRD. [pmid: 16414334].
Low Dog T., Powell K. L., Weisman S. M. Critical evaluation of the safety of Cimicifuga racemosa in menopause symptom relief. Menopause. 2003;10(4):299-313. NRD. [pmid: 12851513].
Lowe G. D. O. Update on the cardiovascular risks of hormone replacement therapy. Women's Health. 2007;3(1):87-97. DES.
Lowe G., Woodward M., Vessey M., Rumley A., Gough P., Daly E. Thrombotic variables and risk of idiopathic venous thromboembolism in women aged 45-64 years. Relationships to hormone replacement therapy. Thromb Haemost. 2000;83(4):530-5. DES. [pmid: 10780311].
Lowry F., Wachter K., Worcester S. Citalopram reduces hot flashes in randomized phase III trial. Oncology Report. 2008;(FALL):104. NCT.
Lufkin E. G., Wahner H. W., O'Fallon W. M., Hodgson S. F., Kotowicz M. A., Lane A. W., Judd H. L., Caplan R. H., Riggs B. L. Treatment of postmenopausal osteoporosis with transdermal estrogen. Ann Intern Med. 1992;117(1):1-9. DES. [pmid: 1534476].
Lumachi F., Frigo A. C., Basso U., Tombolan V., Ermani M. Estrogen therapy and risk of breast cancer in postmenopausal women: a case-control study and results of a multivariate analysis. Menopause. 2010;17(3):524-8. DES. [pmid: 20130492].
Lund E., Bakken K., Dumeaux V., Andersen V., Kumle M. Hormone replacement therapy and breast cancer in former users of oral contraceptives--The Norwegian Women and Cancer study. Int J Cancer. 2007;121(3):645-8. DES. [pmid: 17372914].
Lyytinen H. K., Dyba T., Ylikorkala O., Pukkala E. I. A case-control study on hormone therapy as a risk factor for breast cancer in Finland: Intrauterine system carries a risk as well. Int J Cancer. 2010;126(2):483-9. DES. [pmid: 19588504].
MacLennan A. H., MacLennan A., Wenzel S., Chambers H. M., Eckert K. Continuous low-dose oestrogen and progestogen hormone replacement therapy: a randomised trial. Med J Aust. 1993;159(2):102-6. NRO. [pmid: 8336583].
MacLennan A., Lester S., Moore V. Oral estrogen replacement therapy versus placebo for hot flushes: a systematic review. Climacteric. 2001;4(1):58-74. NRD. [pmid: 11379379].
Maclaran K., Stevenson J. C. Primary prevention of cardiovascular disease with HRT. Womens Health (Lond Engl). 2012;8(1):63-74. NCT. [pmid: 22171776].
Maclennan A. H., Broadbent J. L., Lester S., Moore V. Oral oestrogen and combined oestrogen/progestogen therapy versus placebo for hot flushes. Cochrane Database Syst Rev. 2004;(4):CD002978. NRD. [pmid: 15495039].
Magliano D. J., Rogers S. L., Abramson M. J., Tonkin A. M. Hormone therapy and cardiovascular disease: a systematic review and meta-analysis. BJOG. 2006;113(1):5-14. PTU. [pmid: 16398764].
Magnusson C., Baron J. A., Correia N., Bergstrom R., Adami H. O., Persson I. Breast-cancer risk following long-term oestrogen- and oestrogen-progestin-replacement therapy. Int J Cancer. 1999;81(3):339-44. DES. [pmid: 10209946].
Magos A. L., Brewster E., Singh R., O'Dowd T., Brincat M., Studd J. W. The effects of norethisterone in postmenopausal women on oestrogen replacement therapy: a model for the premenstrual syndrome. Br J Obstet Gynaecol. 1986;93(12):1290-6. NOP. [pmid: 3801360].
Mahady G. B., Fabricant D., Chadwick L. R., Dietz B. Black cohosh: an alternative therapy for menopause?. Nutr Clin Care. 2002;5(6):283-9. NRD. [pmid: 12557811].
Maheux R., Naud F., Rioux M., Grenier R., Lemay A., Guy J., Langevin M. A randomized, double-blind, placebo-controlled study on the effect of conjugated estrogens on skin thickness. Am J Obstet Gynecol. 1994;170(2):642-9. NRO. [pmid: 8116726].
Maki P. M., Sundermann E. Hormone therapy and cognitive function. Hum Reprod Update. 2009;15(6):667-81. NRO. [pmid: 19468050].
Mallmin H., Ljunghall S., Persson I., Bergstrom R. Risk factors for fractures of the distal forearm: a population-based case-control study. Osteoporos Int. 1994;4(6):298-304. DES. [pmid: 7696821].
Mamdani M. M., Tu K., van Walraven C., Austin P. C., Naylor C. D. Postmenopausal estrogen replacement therapy and increased rates of cholecystectomy and appendectomy. CMAJ. 2000;162(10):1421-4. DES. [pmid: 10834045].
Manjer J., Malina J., Berglund G., Bondeson L., Garne J. P., Janzon L. Increased incidence of small and well-differentiated breast tumours in post-menopausal women following hormone-replacement therapy. Int J Cancer. 2001;92(6):919-22. DES. [pmid: 11351317].
Manonai J., Chittacharoen A., Theppisai U., Theppisai H. Effect of Pueraria mirifica on vaginal health. Menopause. 2007;14(5):919-24. NOP. [pmid: 17415017].
Manonai J., Songchitsomboon S., Chanda K., Hong J. H., Komindr S. The effect of a soy-rich diet on urogenital atrophy: a randomized, cross-over trial. Maturitas. 2006;54(2):135-40. NOP. [pmid: 16297576].
Manonai J., Theppisai U., Suthutvoravut S., Udomsubpayakul U., Chittacharoen A. The effect of estradiol vaginal tablet and conjugated estrogen cream on urogenital symptoms in postmenopausal women: a comparative study. J Obstet Gynaecol Res. 2001;27(5):255-60. NOP. [pmid: 11776507].
Manson J. E. Postmenopausal hormone therapy and atherosclerotic disease. Am Heart J. 1994;128(6 Pt 2):1337-43. NCT. [pmid: 7977016].
Manson J. E., Hsia J., Johnson K. C., Rossouw J. E., Assaf A. R., Lasser N. L., Trevisan M., Black H. R., Heckbert S. R., Detrano R., Strickland O. L., Wong N. D., Crouse J. R., Stein E., Cushman M. Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med. 2003;349(6):523-34. DES. [pmid: 12904517].
Marchbanks P. A., McDonald J. A., Wilson H. G., Folger S. G., Mandel M. G., Daling J. R., Bernstein L., Malone K. E., Ursin G., Strom B. L., Norman S. A., Wingo P. A., Burkman R. T., Berlin J. A., Simon M. S., Spirtas R., Weiss L. K. Oral contraceptives and the risk of breast cancer. N Engl J Med. 2002;346(26):2025-32. DES. [pmid: 12087137].
Marchesoni D., Mozzanega B., Maggino T., Nardelli G. B. Postmenopausal hot flushes: Endocrine correlations and progestinic treatment. Double blind crossed clinical trial using MPA versus placebo. Journal of Gynaecological Endocrinology. 1985;1(1-2):63-69. NOP.
Marslew U., Riis B. J., Christiansen C. Desogestrel in hormone replacement therapy: long-term effects on bone, calcium and lipid metabolism, climacteric symptoms, and bleeding. Eur J Clin Invest. 1991;21(6):601-7. NOP. [pmid: 1838079].
Marslew U., Riis B. J., Christiansen C. Bleeding patterns during continuous combined estrogen-progestogen therapy. Am J Obstet Gynecol. 1991;164(5 Pt 1):1163-8. NOP. [pmid: 1827947].
Marslew U., Riis B., Christiansen C. Progestogens: therapeutic and adverse effects in early post-menopausal women. Maturitas. 1991;13(1):7-16. NOP. [pmid: 1830636].
Marslew U., Overgaard K., Riis B. J., Christiansen C. Two new combinations of estrogen and progestogen for prevention of postmenopausal bone loss: long-term effects on bone, calcium and lipid metabolism, climacteric symptoms, and bleeding. Obstet Gynecol. 1992;79(2):202-10. NOP. [pmid: 1309944].
Marslew U., Munk-Nielsen N., Nilas L., Riis B. J., Christiansen C. Bleeding pattern and climacteric symptoms during different sequential combined HRT regimens in current use. Maturitas. 1994;19(3):225-37. NOP. [pmid: 7799829].
Marx P., Schade G., Wilbourn S., Blank S., Moyer D. L., Nett R. Low-dose (0.3 mg) synthetic conjugated estrogens A is effective for managing atrophic vaginitis. Maturitas. 2004;47(1):47-54. NRO. [pmid: 14706765].
Maskarinec G. Soy foods and cancer risk: How does the relation vary in individuals with different ethnicity, diet, and lifestyle?. Cancer Prevention Research. 2010;3(12). NRD.
Mason P. Isoflavones. Pharmaceutical Journal. 2001;266(7129):16-19. NCT.
Mattsson L. A., Skouby S. O., Heikkinen J., Vaheri R., Maenpaa J., Timonen U. A low-dose start in hormone replacement therapy provides a beneficial bleeding profile and few side-effects: randomized comparison with a conventional-dose regimen. Climacteric. 2004;7(1):59-69. NRO. [pmid: 15259284].
Mattsson L. A., Skouby S., Rees M., Heikkinen J., Kudela M., Stadnicki-Kolendo A., Mattila L., Salminen K., Vuorela A., Mustonen M. Efficacy and tolerability of continuous combined hormone replacement therapy in early postmenopausal women. Menopause Int. 2007;13(3):124-31. DUP. [pmid: 17785038].
Maxim P., Ettinger B., Spitalny G. M. Fracture protection provided by long-term estrogen treatment. Osteoporos Int. 1995;5(1):23-9. DES. [pmid: 7703620].
McKay A., Alexander J. L., Kotz K., Dennerstein L., et al. (2004). The effects of postmenopausal hormone therapies on female sexual functioning: A review of double-blind, randomized controlled trials. Menopause. Canadian Journal of Human Sexuality. 13. 2004;11(2):749-765. 126. NRD. [pmid: 15543027].
McDonald J. A., Weiss N. S., Daling J. R., Francis A. M., Polissar L. Menopausal estrogen use and the risk of breast cancer. Breast Cancer Res Treat. 1986;7(3):193-9. DES. [pmid: 3779117].
McMillan T. L., Mark S. Complementary and alternative medicine and physical activity for menopausal symptoms. J Am Med Womens Assoc. 2004;59(4):270-7. NRD. [pmid: 16845756].
McDonald T. W., Annegers J. F., O'Fallon W. M., Dockerty M. B., Malkasian G. D. Jr., Kurland L. T. Exogenous estrogen and endometrial carcinoma: case-control and incidence study. Am J Obstet Gynecol. 1977;127(6):572-80. DES. [pmid: 190887].
McKeon V. A. Hormone replacement therapy: evaluating the risks and benefits. J Obstet Gynecol Neonatal Nurs. 1994;23(8):647-57. NCT.
Mendoza N., Pison J. A., Fernandez M., Sanchez M. C., Malde J., Miranda J. A. Prospective, randomised study with three HRT regimens in postmenopausal women with an intact uterus. Maturitas. 2002;41(4):289-98. NRC. [pmid: 12034516].
Merz C. N. B. Hormone therapy and cardiovascular risk: Why the new focus on perimenopausal women?. Advanced Studies in Medicine. 2006;6(6):267-274. NCT.
Mhurchu C. N., Anderson C., Jamrozik K., Hankey G., Dunbabin D. Hormonal factors and risk of aneurysmal subarachnoid hemorrhage: an international population-based, case-control study. Stroke. 2001;32(3):606-12. DES. [pmid: 11239175].
Miller J., Chan B. K., Nelson H. D. Postmenopausal estrogen replacement and risk for venous thromboembolism: a systematic review and meta-analysis for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;136(9):680-90. PTU. [pmid: 11992304].
Miller J., Chan B. K. S., Nelson H. Hormone Replacement Therapy and Risk of Venous Thromboembolism. [Internet]. 2002. PTU.
Miller R. G., Ashar B. H. Managing menopause: Current therapeutic options for vasomotor symptoms. Advanced Studies in Medicine. 2004;4(9):484-492+494. NRD.
Mills K., Beeson P. W. L., Phillips R. L., Fraser G. E. Prospective study of exogenous hormone use and breast cancer in Seventh-day Adventists. Cancer. 1989;64(3):591-7. DES. [pmid: 2743253].
Mirkin S., Komm B. S. Tissue-selective estrogen complexes for postmenopausal women. Maturitas. 2013;76:213-220. NRD. [pmid: 23849704].
Mizunuma H., Honjo H., Aso T., Urabe M., Ohta H., Kobayashi S., Sagara Y., Sanada M., Tanaka K., Dobashi K., Hayashi K., Ohama K. Postmenopausal hormone replacement therapy use and risk of endometrial cancer in Japanese women. Climacteric. 2001;4(4):293-8. DES. [pmid: 11770185].
Modelska K., Cummings S. Female sexual dysfunction in postmenopausal women: systematic review of placebo-controlled trials. Am J Obstet Gynecol. 2003;188(1):286-93. NRD. [pmid: 12548231].
Modugno F., Kip K. E., Cochrane B., Kuller L., Klug T. L., Rohan T. E., Chlebowski R. T., Lasser N., Stefanick M. L. Obesity, hormone therapy, estrogen metabolism and risk of postmenopausal breast cancer. Int J Cancer. 2006;118(5):1292-301. DES. [pmid: 16161054].
Moe K. E. Hot flashes and sleep in women. Sleep Med Rev. 2004;8(6):487-97. NCT. [pmid: 15556380].
Mohandas B., Mehta J. L. Lessons from hormone replacement therapy trials for primary prevention of cardiovascular disease. Curr Opin Cardiol. 2007;22(5):434-42. NCT. [pmid: 17762545].
Montgomery J. C., Appleby L., Brincat M., Versi E., Tapp A., Fenwick P. B., Studd J. W. Effect of oestrogen and testosterone implants on psychological disorders in the climacteric. Lancet. 1987;1(8528):297-9. NOP. [pmid: 2880114].
Moorman P. G., Kuwabara H., Millikan R. C., Newman B. Menopausal hormones and breast cancer in a biracial population. Am J Public Health. 2000;90(6):966-71. DES. [pmid: 10846517].
Moorman P. G., Schildkraut J. M., Calingaert B., Halabi S., Berchuck A. Menopausal hormones and risk of ovarian cancer. Am J Obstet Gynecol. 2005;193(1):76-82. DES. [pmid: 16021062].
Morch L. S., Lokkegaard E., Andreasen A. H., Kjaer S. K., Lidegaard O. Hormone therapy and different ovarian cancers: a national cohort study. Am J Epidemiol. 2012;175(12):1234-42. NRD. [pmid: 22517811].
Morch L. S., Lokkegaard E., Andreasen A. H., Kruger-Kjaer S., Lidegaard O. Hormone therapy and ovarian cancer. JAMA. 2009;302(3):298-305. DES. [pmid: 19602689].
Morimoto L. M., Newcomb P. A., Hampton J. M., Trentham-Dietz A. Cholecystectomy and endometrial cancer: a marker of long-term elevated estrogen exposure?. Int J Gynecol Cancer. 2006;16(3):1348-53. DES. [pmid: 16803528].
Morois S., Fournier A., Clavel-Chapelon F., Mesrine S., Boutron-Ruault M. C. Menopausal hormone therapy and risks of colorectal adenomas and cancers in the French E3N prospective cohort: true associations or bias?. Eur J Epidemiol. 2012;27(6):439-52. NCT. [pmid: 22644109].
Morris E. P., Rymer J. Menopausal symptoms. Clin Evid (Online) 2007. 2007. DUP.
Mosca L. The role of hormone replacement therapy in the prevention of postmenopausal heart disease. Arch Intern Med. 2000;160(15):2263-72. NCT. [pmid: 10927722].
Mourits M. J., GH B. D. E. Exogenous steroids for menopausal symptoms and breast/endometrial cancer risk. Int J Gynecol Cancer. Suppl 2. 2006;16:494-6. NCT. [pmid: 17010054].
Moyer V. A. Menopausal hormone therapy for the primary prevention of chronic conditions: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013;158(1):47-54. NCT. [pmid: 23090711].
Mueck A. O., Seeger H., Rabe T. Hormonal contraception and risk of endometrial cancer: a systematic review. Endocr Relat Cancer. 2010;17(4):R263-71. NRQ. [pmid: 20870686].
Nachtigall L. E. Clinical trial of the estradiol vaginal ring in the U.S. Maturitas. Suppl. 1995;22:S43-7. NRO. [pmid: 8775777].
Nachtigall L. E., Nachtigall R. H., Nachtigall R. D., Beckman E. M. Estrogen replacement therapy II: a prospective study in the relationship to carcinoma and cardiovascular and metabolic problems. Obstet Gynecol. 1979;54(1):74-9. DES. [pmid: 221871].
Nachtigall L. E., Baber R. J., Barentsen R., Durand N., Panay N., Pitkin J., van de Weijer P. H., Wysocki S. Complementary and hormonal therapy for vasomotor symptom relief: a conservative clinical approach. J Obstet Gynaecol Can. 2006;28(4):279-89. NRD. [pmid: 16776904].
Nachtigall L., Casson P., Lucas J., Schofield V., Melson C., Simon J. A. Safety and tolerability of testosterone patch therapy for up to 4 years in surgically menopausal women receiving oral or transdermal oestrogen. Gynecol Endocrinol. 2011;27(1):39-48. NRO. [pmid: 21142609].
Nagata C., Mizoue T., Tanaka K., Tsuji I., Tamakoshi A., Matsuo K., Wakai K., Inoue M., Tsugane S., Sasazuki S. Soy Intake and Breast Cancer Risk: An Evaluation Based on a Systematic Review of Epidemiologic Evidence Among the Japanese Population. Jpn J Clin Oncol. 2014. NRC.
Nahidi F., Zare E., Mojab F., Alavi-Majd H. Effects of licorice on relief and recurrence of menopausal hot flashes. Iranian Journal of Pharmaceutical Research. 2012;11(2):541-548. NRF. [pmid: 24250477].
Nahum G. G., Stanislaw H., Simon J. A. Stopping menopausal hormone therapy: if breast cancer really decreased, why did colorectal cancer not increase?. Maturitas. 2012;71(4):354-9. NCT. [pmid: 22300685].
Nair G. V., Chaput L. A., Vittinghoff E., Herrington D. M. Pulse pressure and cardiovascular events in postmenopausal women with coronary heart disease. Chest. 2005;127(5):1498-506. DES. [pmid: 15888820].
Nand S. L., Webster M. A., Baber R., Heller G. Z. Menopausal symptom control and side-effects on continuous estrone sulfate and three doses of medroxyprogesterone acetate. Ogen/Provera Study Group. Climacteric. 1998;1(3):211-8. NRC. [pmid: 11913409].
Nanda K., Bastian L. A., Hasselblad V., Simel D. L. Hormone replacement therapy and the risk of colorectal cancer: a meta-analysis. Obstet Gynecol. 1999;93(5 Pt 2):880-8. PTU. [pmid: 10912438].
Nappi R. E., Polatti F. The use of estrogen therapy in women's sexual functioning (CME). J Sex Med. 2009;6(3):603-16. quiz 618-9. NRD. [pmid: 19284468].
Nappi R. E., Davis S. R. The use of hormone therapy for the maintenance of urogynecological and sexual health post WHI. Climacteric. 2012;15(3):267-274. NRD. [pmid: 22612614].
Nastri C. O., Lara L. A., Ferriani R. A., Rosa E. S. A. C., Figueiredo J. B., Martins W. P. Hormone therapy for sexual function in perimenopausal and postmenopausal women. Cochrane Database Syst Rev. 2013;6:CD009672. NRD. [pmid: 23737033].
Nathorst-Boos J., Wiklund I., Mattsson L. A., Sandin K., von Schoultz B. Is sexual life influenced by transdermal estrogen therapy? A double blind placebo controlled study in postmenopausal women. Acta Obstet Gynecol Scand. 1993;72(8):656-60. NRO. [pmid: 8259754].
Nazeri K., Khatibi A., Nyberg P., Agardh C. D., Lidfeldt J., Samsioe G. Colorectal cancer in middle-aged women in relation to hormonal status: a report from the Women's Health in the Lund Area (WHILA) study. Gynecol Endocrinol. 2006;22(8):416-22. DES. [pmid: 17012102].
Nedrow A., Miller J., Walker M., Nygren P., Huffman L. H., Nelson H. D. Complementary and alternative therapies for the management of menopause-related symptoms: a systematic evidence review. Arch Intern Med. 2006;166(14):1453-65. NRD. [pmid: 16864755].
Negri E., Tzonou A., Beral V., Lagiou P., Trichopoulos D., Parazzini F., Franceschi S., Booth M., La Vecchia C. Hormonal therapy for menopause and ovarian cancer in a collaborative re-analysis of European studies. Int J Cancer. 1999;80(6):848-51. DES. [pmid: 10074916].
Nelson H. D. Hormone Replacement Therapy and Osteoporosis. [Internet]. 2002. PTU.
Nelson H. D. Commonly used types of postmenopausal estrogen for treatment of hot flashes: scientific review. JAMA. 2004;291(13):1610-20. NRD. [pmid: 15069049].
Nelson H. D., Haney E., Humphrey L., Miller J., Nedrow A., Nicolaidis C., Vesco K., Walker M., Bougatsos C., Nygren P. Management of menopause-related symptoms. Evid Rep Technol Assess (Summ). 2005;(120):1-6. NRD. [pmid: 15910013].
Nelson H. D., Rizzo J., Harris E., Cauley J., Ensrud K., Bauer D. C., Orwoll E. Osteoporosis and fractures in postmenopausal women using estrogen. Arch Intern Med. 2002;162(20):2278-84. DES. [pmid: 12418942].
Nelson H. D., Vesco K. K., Haney E., Fu R., Nedrow A., Miller J., Nicolaidis C., Walker M., Humphrey L. Nonhormonal therapies for menopausal hot flashes: systematic review and meta-analysis. JAMA. 2006;295(17):2057-71. NRD. [pmid: 16670414].
Nelson H. D., Humphrey L. L., Nygren P., Teutsch S. M., Allan J. D. Postmenopausal hormone replacement therapy: scientific review. JAMA. 2002;288(7):872-81. PTU. [pmid: 12186605].
Nelson H. D., Walker M., Zakher B., Mitchell J. Menopausal hormone therapy for the primary prevention of chronic conditions: a systematic review to update the U.S. Preventive Services Task Force recommendations. Ann Intern Med. 2012;157(2):104-13. DUP. [pmid: 22786830].
Nesheim B. I., Saetre T. Reduction of menopausal hot flushes by methyldopa. A double blind crossover trial. Eur J Clin Pharmacol. 1981;20(6):413-6. NOP. [pmid: 7026262].
Ness R. B., Albano J. D., McTiernan A., Cauley J. A. Influence of estrogen plus testosterone supplementation on breast cancer. Arch Intern Med. 2009;169(1):41-6. DES. [pmid: 19139322].
Newcomb P. A., Trentham-Dietz A. Patterns of postmenopausal progestin use with estrogen in relation to endometrial cancer (United States). Cancer Causes Control. 2003;14(2):195-201. DES. [pmid: 12749724].
Newcomb P. A., Taylor J. O., Trentham-Dietz A. Interactions of familial and hormonal risk factors for large bowel cancer in women. Int J Epidemiol. 1999;28(4):603-8. DES. [pmid: 10480684].
Newcomb P. A., Titus-Ernstoff L., Egan K. M., Trentham-Dietz A., Baron J. A., Storer B. E., Willett W. C., Stampfer M. J. Postmenopausal estrogen and progestin use in relation to breast cancer risk. Cancer Epidemiol Biomarkers Prev. 2002;11(7):593-600. DES. [pmid: 12101105].
Newcomb P. A., Longnecker M. P., Storer B. E., Mittendorf R., Baron J., Clapp R. W., Bogdan G., Willett W. C. Long-term hormone replacement therapy and risk of breast cancer in postmenopausal women. Am J Epidemiol. 1995;142(8):788-95. DES. [pmid: 7572954].
Newcomer L. M., Newcomb P. A., Trentham-Dietz A., Storer B. E. Hormonal risk factors for endometrial cancer: modification by cigarette smoking (United States). Cancer Causes Control. 2001;12(9):829-35. DES. [pmid: 11714111].
Newcomer L. M., Newcomb P. A., Potter J. D., Yasui Y., Trentham-Dietz A., Storer B. E., Longnecker M. P., Baron J. A., Daling J. R. Postmenopausal hormone therapy and risk of breast cancer by histologic type (United States). Cancer Causes Control. 2003;14(3):225-33. DES. [pmid: 12814201].
Ni X. J., Xia T. S., Zhao Y. C., Ma J. J., Zhao J., Liu X. A., Ding Q., Zha X. M., Wang S. Postmenopausal Hormone Therapy is Associated with in Situ Breast Cancer Risk. Asian Pac J Cancer Prev. 2012;13(8):3917-25. NRQ. [pmid: 23098493].
Nicholson W. K., Brown A. F., Gathe J., Grumbach K., Washington A. E., Perez-Stable E. J. Hormone replacement therapy for African American women: missed opportunities for effective intervention. Menopause. 1999;6(2):147-55. NRQ. [pmid: 10374222].
Nikander E., Rutanen E. M., Nieminen P., Wahlstrom T., Ylikorkala O., Tiitinen A. Lack of effect of isoflavonoids on the vagina and endometrium in postmenopausal women. Fertil Steril. 2005;83(1):137-42. NRO. [pmid: 15652899].
Nomura A., Hirohata T., Kolonel L., Hankin J. Diet and exogenous estrogens in three populations at different levels of risk for breast cancer. Natl Cancer Inst Monogr. 1977;47:165-7. DES. [pmid: 613237].
Nordin B. E., Jones M. M., Crilly R. G., Marshall D. H., Brooke R. A placebo-controlled trial of ethinyl oestradiol and norethisterone in climacteric women. Maturitas. 1980;2(3):247-51. NOP. [pmid: 7003315].
Norman S. A., Weber A. L., Localio A. R., Marchbanks P. A., Ursin G., Strom B. L., Weiss L. K., Burkman R. T., Bernstein L., Deapen D. M., Folger S. G., Simon M. S., Nadel M. R. Hormone therapy and fatal breast cancer. Pharmacoepidemiol Drug Saf. 2010;19(5):440-7. DES. [pmid: 20336635].
Norman S. A., Berlin J. A., Weber A. L., Strom B. L., Daling J. R., Weiss L. K., Marchbanks P. A., Bernstein L., Voigt L. F., McDonald J. A., Ursin G., Liff J. M., Burkman R. T., Malone K. E., Simon M. S., Folger S. G., Deapen D., Wingo P. A., Spirtas R. Combined effect of oral contraceptive use and hormone replacement therapy on breast cancer risk in postmenopausal women. Cancer Causes Control. 2003;14(10):933-43. DES. [pmid: 14750532].
Obel E. B., Munk-Jensen N., Svenstrup B., Bennett P., Micic S., Henrik-Nielsen R., Nielsen S. P., Gydesen H., Jensen B. M. A two-year double-blind controlled study of the clinical effect of combined and sequential postmenopausal replacement therapy and steroid metabolism during treatment. Maturitas. 1993;16(1):13-21. DUP. [pmid: 8429800].
Obi N., Chang-Claude J., Berger J., Braendle W., Slanger T., Schmidt M., Steindorf K., Ahrens W., Flesch-Janys D. The use of herbal preparations to alleviate climacteric disorders and risk of postmenopausal breast cancer in a German case-control study. Cancer Epidemiol Biomarkers Prev. 2009;18(8):2207-13. NRD. [pmid: 19661079].
Odem R. R., Moniz M. H., Allsworth J. E., Bleckman C. R., Omicioli V. A., Lawrence L. T., Thaker P. H. Long-term postmenopausal hormone therapy and endometrial cancer risk: a study by Doherty et al. Am J Obstet Gynecol. 2007;197(2):213-4. discussion e1-5. DES. [pmid: 17689656].
Odmark I. S., Backstrom T., Jonsson B., Bixo M. Long-term effects of two different continuous combined regimens of hormone replacement therapy on well-being. Gynecol Endocrinol. 2004;18(6):305-17. NRC. [pmid: 15497493].
Oestrogen plus progestin hormone replacement therapy increases venous thrombosis in postmenopausal women. Evidence-Based Healthcare and Public Health. 2005;9(2):159-160. DES.
Oestrogen increases the risk of stroke but has no effect on coronary heart disease in healthy post-menopausal women. Evidence-Based Healthcare and Public Health. 2004;8(5):308-309. DES.
Oh K. J., Chae M. J., Lee H. S., Hong H. D., Park K. Effects of Korean red ginseng on sexual arousal in menopausal women: placebo-controlled, double-blind crossover clinical study. J Sex Med. 2010;7(4 Pt 1):1469-77. NOP. [pmid: 20141583].
Ohira T., Folsom A. R., Cushman M., White R. H., Hannan P. J., Rosamond W. D., Heckbert S. R. Reproductive history, hormone replacement, and incidence of venous thromboembolism: the Longitudinal Investigation of Thromboembolism Etiology. Br J Haematol. 2010;149(4):606-12. DES. [pmid: 20230397].
Olie V., Canonico M., Scarabin P. Y. Postmenopausal hormone therapy and venous thromboembolism. Thromb Res. Suppl 3. 2011;127:S26-9. PTU. [pmid: 21262434].
Olie V., Canonico M., Scarabin P. Y. Risk of venous thrombosis with oral versus transdermal estrogen therapy among postmenopausal women. Curr Opin Hematol. 2010;17(5):457-63. PTU. [pmid: 20601871].
Olsson H. L., Ingvar C., Bladstrom A. Hormone replacement therapy containing progestins and given continuously increases breast carcinoma risk in Sweden. Cancer. 2003;97(6):1387-92. DES. [pmid: 12627501].
Olsson H., Bladstrom A., Ingvar C. Are smoking-associated cancers prevented or postponed in women using hormone replacement therapy?. Obstet Gynecol. 2003;102(3):565-70. DES. [pmid: 12962944].
Olsson H., Bladstrom A., Ingvar C., Moller T. R. A population-based cohort study of HRT use and breast cancer in southern Sweden. Br J Cancer. 2001;85(5):674-7. DES. [pmid: 11531250].
Olver I. N. Hormone replacement therapy: The need to combine clinical and epidemiological data. Cancer Forum. 2012;36(3). NCT.
Opatrny L., Dell'Aniello S., Assouline S., Suissa S. Hormone replacement therapy use and variations in the risk of breast cancer. BJOG. 2008;115(2):169-75. discussion 175. DES. [pmid: 18081598].
Ortmann O., Lattrich C. The treatment of climacteric symptoms. Dtsch Arztebl Int. 2012;109(17):316-23. quiz 324. NRD. [pmid: 22611453].
Ovarian cancer and body size: individual participant meta-analysis including 25,157 women with ovarian cancer from 47 epidemiological studies. PLoS Med. 2012;9(4):e1001200. NRQ. [pmid: 22606070].
Padwick M. L., Siddle N. C., Lane G., Endacott J. A., Cooper H., Pryse-Davies J., Whitehead M. I. Oestriol with oestradiol verses oestradiol alone: a comparison of endometrial, symptomatic and psychological effects. Br J Obstet Gynaecol. 1986;93(6):606-12. NOP. [pmid: 3524665].
Paganini-Hill A. Estrogen replacement therapy in the elderly. Zentralbl Gynakol. 1996;118(5):255-61. DES. [pmid: 8701621].
Paganini-Hill A., Ross R. K., Henderson B. E. Endometrial cancer and patterns of use of oestrogen replacement therapy: a cohort study. Br J Cancer. 1989;59(3):445-7. DES. [pmid: 2930713].
Paganini-Hill A., Ross R. K., Henderson B. E. Postmenopausal oestrogen treatment and stroke: a prospective study. BMJ. 1988;297(6647):519-22. DES. [pmid: 3139181].
Pal L., Hailpern S. M., Santoro N. F., Freeman R., Barad D., Kipersztok S., Barnabei V. M., Wassertheil-Smoller S. Increased incident hip fractures in postmenopausal women with moderate to severe pelvic organ prolapse. Menopause. 2011;18(9):967-973. DES. [pmid: 21738078].
Palacio C., Masri G., Mooradian A. D. Black cohosh for the management of menopausal symptoms : a systematic review of clinical trials. Drugs Aging. 2009;26(1):23-36. NRD. [pmid: 19102512].
Palacios S. Managing urogenital atrophy. Maturitas. 2009;63(4):315-8. NRD. [pmid: 19493638].
Panahi Y., Beiraghdar F., Kashani N., Javan N. B., Dadjo Y. Comparison of piascledine (Avocado and Soybean oil) and hormone replacement therapy in menopausal-induced hot flashing. Iranian Journal of Pharmaceutical Research. 2011;10(4):941-951. NOP. [pmid: 24250433].
Panay N. Taking an integrated approach: managing women with phytoestrogens. Climacteric. Suppl 2. 2011;14:2-7. NCT. [pmid: 22074008].
Panay N., Toth K., Pelissier C., Studd J. Dose-ranging studies of a novel intranasal estrogen replacement therapy. Maturitas. Suppl 1. 2001;38:S15-22. NOP. [pmid: 11390120].
Panjari M., Davis S. R. DHEA for postmenopausal women: a review of the evidence. Maturitas. 2010;66(2):172-9. NRD. [pmid: 20089375].
Panjari M., Davis S. R. DHEA therapy for women: effect on sexual function and wellbeing. Hum Reprod Update. 2007;13(3):239-48. NRD. [pmid: 17208951].
Panjari M., Davis S. R. Vaginal DHEA to treat menopause related atrophy: a review of the evidence. Maturitas. 2011;70(1):22-5. NRD. [pmid: 21733647].
Panjari M., Bell R. J., Jane F., Adams J., Morrow C., Davis S. R. The safety of 52 weeks of oral DHEA therapy for postmenopausal women. Maturitas. 2009;63(3):240-5. NRO. [pmid: 19410392].
Parazzini F., Negri E., La Vecchia C., Bruzzi P., Decarli A. Population attributable risk for endometrial cancer in northern Italy. Eur J Cancer Clin Oncol. 1989;25(10):1451-6. DES. [pmid: 2591436].
Park B. D., Lookinland S., Beckstrand R. L., Chasson S. Factor V Leiden and venous thromboembolism: risk associated with hormone replacement therapy. J Am Acad Nurse Pract. 2003;15(10):458-66. PTU. [pmid: 14606135].
Parry B. L., Meliska C. J., Martinez L. F., Basavaraj N., Zirpoli G. G., Sorenson D., Maurer E. L., Lopez A., Markova K., Gamst A., Wolfson T., Hauger R., Kripke D. F. Menopause: neuroendocrine changes and hormone replacement therapy. J Am Med Womens Assoc. 2004;59(2):135-45. NOP. [pmid: 15134429].
Pasco J. A., Kotowicz M. A., Henry M. J., Sanders K. M., Nicholson G. C. Health outcomes associated with hormone therapy in Australian women. Curr Drug Saf. 2009;4(3):169-72. DES. [pmid: 19534644].
Pearce C. L., Chung K., Pike M. C., Wu A. H. Increased ovarian cancer risk associated with menopausal estrogen therapy is reduced by adding a progestin. Cancer. 2009;115(3):531-9. PTU. [pmid: 19127543].
Pedersen S. H., Lokkegaard E., Ottesen B. Hormone theraphy and cardiovascular risk markers and disease: Focus on progestagens. Future Cardiology. 2006;2(6):677-686. DES. [pmid: 19804260].
Peeyananjarassri K., Baber R. Effects of low-dose hormone therapy on menopausal symptoms, bone mineral density, endometrium, and the cardiovascular system: a review of randomized clinical trials. Climacteric. 2005;8(1):13-23. NRO. [pmid: 15804728].
Pelissier C., Maroni M., Yaneva H., Brin S., Peltier-Pujol F., Jondet M. Chlormadinone acetate versus micronized progesterone in the sequential combined hormone replacement therapy of the menopause. Maturitas. 2001;40(1):85-94. NRC. [pmid: 11684377].
Pentti K., Honkanen R., Tuppurainen M. T., Sandini L., Kroger H., Saarikoski S. Hormone replacement therapy and mortality in 52- to 70-year-old women: the Kuopio Osteoporosis Risk Factor and Prevention Study. Eur J Endocrinol. 2006;154(1):101-7. DES. [pmid: 16381998].
Perez-Lopez F. R., Chedraui P., Gilbert J. J., Perez-Roncero G. Cardiovascular risk in menopausal women and prevalent related co-morbid conditions: facing the post-Women's Health Initiative era. Fertil Steril. 2009;92(4):1171-86. PTU. [pmid: 19700149].
Perez-Castrillon J. L., De Luis D., Hernandez G., Duenas-Laita A. Isoflavones and bone health. Current Women's Health Reviews. 2009;5(3):125-129. NRO.
Perlman J. A., Wolf P. H., Ray R., Lieberknecht G. Cardiovascular risk factors, premature heart disease, and all-cause mortality in a cohort of northern California women. Am J Obstet Gynecol. 1988;158(6 Pt 2):1568-74. DES. [pmid: 3377034].
Persson I. The risk of endometrial and breast cancer after estrogen treatment. A review of epidemiological studies. Acta Obstet Gynecol Scand Suppl. 1985;130:59-66. NCT. [pmid: 3859977].
Persson I., Adami H. O., Lindberg B. S., Johansson E. D., Manell P. Characteristics of estrogen-treated women. A descriptive epidemiological study of a Swedish population. Part II. Acta Obstet Gynecol Scand. 1983;62(4):297-302. DES. [pmid: 6637403].
Persson I. R., Adami H. O., Eklund G., Johansson E. D., Lindberg B. S., Lindgren A. The risk of endometrial neoplasia and treatment with estrogens and estrogen-progestogen combinations. First results of a cohort study after one to four completed years of observation. Acta Obstet Gynecol Scand. 1986;65(3):211-7. DES. [pmid: 3739627].
Pesch B., Ko Y., Brauch H., Hamann U., Harth V., Rabstein S., Pierl C., Fischer H. P., Baisch C., Justenhoven C., Ranft U., Bruning T. Factors modifying the association between hormone-replacement therapy and breast cancer risk. Eur J Epidemiol. 2005;20(8):699-711. DES. [pmid: 16151884].
Peterson G. M., Naunton M., Tichelaar L. K., Gennari L. Lasofoxifene: selective estrogen receptor modulator for the prevention and treatment of postmenopausal osteoporosis. Ann Pharmacother. 2011;45(4):499-509. NRQ. [pmid: 21467260].
Petitti D. B., Sidney S., Quesenberry C. P. Jr. Hormone replacement therapy and the risk of myocardial infarction in women with coronary risk factors. Epidemiology. 2000;11(5):603-6. DES. [pmid: 10955415].
Petitti D. B., Sidney S., Perlman J. A. Increased risk of cholecystectomy in users of supplemental estrogen. Gastroenterology. 1988;94(1):91-5. DES. [pmid: 3335303].
Petitti D. B., Sidney S., Quesenberry C. P. Jr., Bernstein A. Ischemic stroke and use of estrogen and estrogen/progestogen as hormone replacement therapy. Stroke. 1998;29(1):23-8. DES. [pmid: 9445323].
Pettersson B., Adami H. O., Persson I., Bergstrom R., Lindgren A., Johansson E. D. Climacteric symptoms and estrogen replacement therapy in women with endometrial carcinoma. Acta Obstet Gynecol Scand. 1986;65(1):81-7. DES. [pmid: 3716786].
Peverill R. E. Hormone therapy and venous thromboembolism. Best Pract Res Clin Endocrinol Metab. 2003;17(1):149-64. NCT. [pmid: 12763518].
Pfeffer R. I., Van Den Noort S. Estrogen use and stroke risk in postmenopausal women. Am J Epidemiol. 1976;103(5):445-56. DES. [pmid: 1274949].
Pfeffer R. I., Whipple G. H., Kurosaki T. T., Chapman J. M. Coronary risk and estrogen use in postmenopausal women. Am J Epidemiol. 1978;107(6):479-97. DES. [pmid: 665662].
Phillips L. S., Langer R. D. Postmenopausal hormone therapy: critical reappraisal and a unified hypothesis. Fertil Steril. 2005;83(3):558-66. NCT. [pmid: 15749481].
Pike M. C., Ross R. K. Progestins and menopause: epidemiological studies of risks of endometrial and breast cancer. Steroids. 2000;65(10-11):659-64. DES. [pmid: 11108873].
Pike M. C., Peters R. K., Cozen W., Probst-Hensch N. M., Felix J. C., Wan P. C., Mack T. M. Estrogen-progestin replacement therapy and endometrial cancer. J Natl Cancer Inst. 1997;89(15):1110-6. DES. [pmid: 9262248].
Pines A. Post-myocardial infarction hormone therapy revisited. Climacteric. 2012;15(6):538-541. NRQ. [pmid: 22640475].
Pines A. SSRIs for hot fl ushes and insomnia. Climacteric. 2012;15(4):403-404. NRD. [pmid: 22950123].
Pines A., Sturdee D. W., MacLennan A. H. Quality of life and the role of menopausal hormone therapy. Climacteric. 2012;15(3):213-216. NRD. [pmid: 22612606].
Pinkerton J. V., Abraham L., Bushmakin A. G., Cappelleri J. C., Racketa J., Shi H., Chines A. A., Mirkin S. Evaluation of the Efficacy and Safety of Bazedoxifene/Conjugated Estrogens for Secondary Outcomes Including Vasomotor Symptoms in Postmenopausal Women by Years Since Menopause in the Selective Estrogens, Menopause and Response to Therapy (SMART) Trials. J Womens Health (Larchmt). 2014;23:18-28. DUP. [pmid: 24206058].
Pinkerton J. V., Santen R. Use of alternatives to estrogen for treatment of menopause. Minerva Endocrinol. 2002;27(1):21-41. NCT. [pmid: 11845111].
Pinkerton J. V., Stovall D. W., Kightlinger R. S. Advances in the treatment of menopausal symptoms. Womens Health (Lond Engl). 2009;5(4):361-384. quiz 383-4. NRD. [pmid: 19586429].
Pinkerton J. V., Kagan R., Portman D., Sathyanarayana R. M., Sweeney M. Efficacy of gabapentin extended release in the treatment of menopausal hot flashes: Results of the breeze 3 study. Menopause. 2012;19(12):1377. DUP.
Pinkerton J. V., Utian W. H., Constantine G. D., Olivier S., Pickar J. H. Relief of vasomotor symptoms with the tissue-selective estrogen complex containing bazedoxifene/conjugated estrogens: a randomized, controlled trial. Menopause. 2009;16(6):1116-24. NRC. [pmid: 19546826].
Pitkin J. Alternative and complementary therapies for the menopause. Menopause Int. 2012;18(1):20-7. NCT. [pmid: 22393177].
Place V. A., Powers M., Darley P. E., Schenkel L., Good W. R. A double-blind comparative study of Estraderm and Premarin in the amelioration of postmenopausal symptoms. Am J Obstet Gynecol. 1985;152(8):1092-9. NRF. [pmid: 2992278].
Polo-Kantola P., Rauhala E., Helenius H., Erkkola R., Irjala K., Polo O. Breathing during sleep in menopause: a randomized, controlled, crossover trial with estrogen therapy. Obstet Gynecol. 2003;102(1):68-75. DUP. [pmid: 12850609].
Polo-Kantola P., Erkkola R., Helenius H., Irjala K., Polo O. When does estrogen replacement therapy improve sleep quality?. Am J Obstet Gynecol. 1998;178(5):1002-9. DUP. [pmid: 9609575].
Polychronopoulou A., Tzonou A., Hsieh C. C., Kaprinis G., Rebelakos A., Toupadaki N., Trichopoulos D. Reproductive variables, tobacco, ethanol, coffee and somatometry as risk factors for ovarian cancer. Int J Cancer. 1993;55(3):402-7. DES. [pmid: 8375923].
Pornel B. Efficacy and safety of Menorest in two positive-controlled studies. Eur J Obstet Gynecol Reprod Biol. Suppl. 1996;64:S35-7. DUP. [pmid: 8732472].
Pornel B., Genazzani A. R., Costes D., Dain M. P., Lelann L., Vandepol C. Efficacy and tolerability of Menorest 50 compared with Estraderm TTS 50 in the treatment of postmenopausal symptoms. A randomized, multicenter, parallel group study. Maturitas. 1995;22(3):207-18. NRC. [pmid: 8746878].
Posthuma W. F., Westendorp R. G., Vandenbroucke J. P. Cardioprotective effect of hormone replacement therapy in postmenopausal women: is the evidence biased?. BMJ. 1994;308(6939):1268-9. NCT. [pmid: 8205018].
Postmenopausal hormone replacement therapy for primary prevention of chronic conditions: recommendations and rationale. Ann Intern Med. 2002;137(10):834-9. NCT. [pmid: 12435221].
Postmenopausal hormone therapy: cardiovascular risks. Prescrire Int. 2003;12(64):65-9. DES. [pmid: 12674130].
Prentice R. L., Manson J. E., Langer R. D., Anderson G. L., Pettinger M., Jackson R. D., Johnson K. C., Kuller L. H., Lane D. S., Wactawski-Wende J., Brzyski R., Allison M., Ockene J., Sarto G., Rossouw J. E. Benefits and risks of postmenopausal hormone therapy when it is initiated soon after menopause. Am J Epidemiol. 2009;170(1):12-23. DES. [pmid: 19468079].
Prentice R. L., Chlebowski R. T., Stefanick M. L., Manson J. E., Pettinger M., Hendrix S. L., Hubbell F. A., Kooperberg C., Kuller L. H., Lane D. S., McTiernan A., Jo O'Sullivan M., Rossouw J. E., Anderson G. L. Estrogen plus progestin therapy and breast cancer in recently postmenopausal women. Am J Epidemiol. 2008;167(10):1207-16. DES. [pmid: 18372396].
Prentice R. L., Chlebowski R. T., Stefanick M. L., Manson J. E., Langer R. D., Pettinger M., Hendrix S. L., Hubbell F. A., Kooperberg C., Kuller L. H., Lane D. S., McTiernan A., O'Sullivan M. J., Rossouw J. E., Anderson G. L. Conjugated equine estrogens and breast cancer risk in the Women's Health Initiative clinical trial and observational study. Am J Epidemiol. 2008;167(12):1407-15. DES. [pmid: 18448442].
Progestagen-only treatment before menopause: increased risk of breast cancer. Prescrire Int. 2008;17(98):243. DES. [pmid: 19422175].
Pruthi S., Qin R., Terstreip S. A., Liu H., Loprinzi C. L., Shah T. R., Tucker K. F., Dakhil S. R., Bury M. J., Carolla R. L., Steen P. D., Vuky J., Barton D. L. A phase III, randomized, placebo-controlled, double-blind trial of flaxseed for the treatment of hot flashes: North Central Cancer Treatment Group N08C7. Menopause. 2012;19(1):48-53. NRF. [pmid: 21900849].
Psaty B. M., Heckbert S. R., Atkins D., Siscovick D. S., Koepsell T. D., Wahl P. W., Longstreth W. T. Jr., Weiss N. S., Wagner E. H., Prentice R., et al. A review of the association of estrogens and progestins with cardiovascular disease in postmenopausal women. Arch Intern Med. 1993;153(12):1421-7. NCT. [pmid: 8512434].
Purdie D. M., Bain C. J., Siskind V., Russell P., Hacker N. F., Ward B. G., Quinn M. A., Green A. C. Hormone replacement therapy and risk of epithelial ovarian cancer. Br J Cancer. 1999;81(3):559-63. DES. [pmid: 10507786].
Qin L. Q., Xu J. Y., Wang P. Y., Hoshi K. Soyfood intake in the prevention of breast cancer risk in women: a meta-analysis of observational epidemiological studies. J Nutr Sci Vitaminol (Tokyo). 2006;52(6):428-36. PTU. [pmid: 17330506].
Quaas A. M., Kono N., Mack W. J., Hodis H. N., Felix J. C., Paulson R. J., Shoupe D. Effect of isoflavone soy protein supplementation on endometrial thickness, hyperplasia, and endometrial cancer risk in postmenopausal women: A randomized controlled trial. Menopause. 2013;20:840-844. NOP. [pmid: 23422867].
Quaas A. M., Kono N., Mack W. J., Hodis H., Paulson R. J., Shoupe D. The effect of isoflavone Soy protein (ISP) supplementation on endometrial thickness, hyperplasia and endometrial cancer risk in postmenopausalwomen: A randomized controlled trial. Fertility and Sterility. 2012;97(3):S6. DUP.
Rabenda V., Bruyere O., Reginster J. Y. Risk of nonvertebral fractures among elderly postmenopausal women using antidepressants. Bone. 2012;51(4):674-679. NRP. [pmid: 22889722].
Racine A., Bijon A., Fournier A., Mesrine S., Clavel-Chapelon F., Carbonnel F., Boutron-Ruault M. C. Menopausal hormone therapy and risk of cholecystectomy: A prospective study based on the French E3N cohort. CMAJ. 2013;185(7):555-561. NCT. [pmid: 23509128].
Racketa J., Pinkerton J. V., Pan K., Abraham L., Chines A. A., Mirkin S. Effects of bazedoxifene/conjugated estrogens on sleep parameters and health-related quality of life in postmenopausal women. Maturitas. 2012;71:S59-S60. DUP.
Ratanawichitrasin A., Reansuwan W., Ratanawichitrasin S., Bhodhisuwan K., Kongpatanakul S. Risk of breast cancer in post-menopausal women using hormone replacement therapy. J Med Assoc Thai. 2002;85(5):583-9. DES. [pmid: 12188389].
Ravdin P. M. Hormone Replacement Therapy and the Increase in the Incidence of Invasive Lobular Cancer. Breast Dis. 2009;30:3-8. NCT. [pmid: 19850989].
Razavi P., Pike M. C., Horn-Ross P. L., Templeman C., Bernstein L., Ursin G. Long-term postmenopausal hormone therapy and endometrial cancer. Cancer Epidemiol Biomarkers Prev. 2010;19(2):475-83. DES. [pmid: 20086105].
Rea T. D., Psaty B. M., Heckbert S. R., Cushman M., Meilahn E., Olson J. L., Lemaitre R. N., Smith N. L., Sotoodehnia N., Chaves P. H. Hormone replacement therapy and the risk of incident congestive heart failure: the Cardiovascular Health Study. J Womens Health (Larchmt). 2003;12(4):341-50. DES. [pmid: 12804341].
Reed S. D., Newton K. M., LaCroix A. Z., Grothaus L. C., Grieco V. S., Ehrlich K. Vaginal, endometrial, and reproductive hormone findings: randomized, placebo-controlled trial of black cohosh, multibotanical herbs, and dietary soy for vasomotor symptoms: the Herbal Alternatives for Menopause (HALT) Study. Menopause. 2008;15(1):51-8. NRO. [pmid: 18257142].
Reed S. D., Voigt L. F., Beresford S. A., Hill D. A., Doherty J. A., Weiss N. S. Dose of progestin in postmenopausal-combined hormone therapy and risk of endometrial cancer. Am J Obstet Gynecol. 2004;191(4):1146-51. DES. [pmid: 15507934].
Rees M. C., Kuhl H., Engelstein M., Mattila L., Maenpaa J., Mustonen M. Endometrial safety and tolerability of triphasic sequential hormone replacement estradiol valerate/medroxyprogesterone acetate therapy regimen. Climacteric. 2004;7(1):23-32. NRC. [pmid: 15259280].
Rees M., Perez-Lopez F. R., Ceasu I., Depypere H., Erel T., Lambrinoudaki I., Schenck-Gustafsson K., Simoncini T., van der Schouw Y., Tremollieres F. EMAS clinical guide: low-dose vaginal estrogens for postmenopausal vaginal atrophy. Maturitas. 2012;73(2):171-4. NRD. [pmid: 22818886].
Rees M. C., Kuhl H., Engelstein M., et al. Endometrial safety and tolerability of triphasic sequential hormone replacement estradiol valerate/medroxyprogesterone acetate therapy regimen. Climacteric. 2004;7(1):23-32. NRC. [pmid: 15259280].
Reeves G. K., Beral V., Green J., Gathani T., Bull D. Hormonal therapy for menopause and breast-cancer risk by histological type: a cohort study and meta-analysis. Lancet Oncol. 2006;7(11):910-8. DES. [pmid: 17081916].
Reginster J. Y., Richy F., Bruyere O. A critical analysis of the efficacy of estrogens on spinal and non-spinal fracture reduction. Reproduction Humaine et Hormones. 2004;17(5):419-423. PTU.
Renoux C., Dell'Aniello S., Suissa S. Hormone replacement therapy and the risk of venous thromboembolism: a population-based study. J Thromb Haemost. 2010;8(5):979-86. DES. [pmid: 20230416].
Renoux C., Dell'aniello S., Garbe E., Suissa S. Hormone replacement therapy use and the risk of stroke. Maturitas. 2008;61(4):305-9. DES. [pmid: 18996656].
Renoux C., Dell'aniello S., Garbe E., Suissa S. Transdermal and oral hormone replacement therapy and the risk of stroke: a nested case-control study. BMJ. 2010;340:c2519. DES. [pmid: 20525678].
Reslan O. M., Khalil R. A. Vascular effects of estrogenic menopausal hormone therapy. Reviews on Recent Clinical Trials. 2012;7(1):47-70. NCT. [pmid: 21864249].
Riman T., Dickman P. W., Nilsson S., Correia N., Nordlinder H., Magnusson C. M., Persson I. R. Risk factors for invasive epithelial ovarian cancer: results from a Swedish case-control study. Am J Epidemiol. 2002;156(4):363-73. DES. [pmid: 12181107].
Riman T., Dickman P. W., Nilsson S., Correia N., Nordlinder H., Magnusson C. M., Weiderpass E., Persson I. R. Hormone replacement therapy and the risk of invasive epithelial ovarian cancer in Swedish women. J Natl Cancer Inst. 2002;94(7):497-504. DES. [pmid: 11929950].
Risch H. A., Howe G. R. Menopausal hormone usage and breast cancer in Saskatchewan: a record-linkage cohort study. Am J Epidemiol. 1994;139(7):670-83. DES. [pmid: 8166128].
Roberts H. Hormone therapy for menopausal symptoms. BMJ. 2012;344:e815. NCT. [pmid: 22318438].
Robinson D., Cardozo L. Urogenital effects of hormone therapy. Best Practice and Research in Clinical Endocrinology and Metabolism. 2003;17(1):91-104. NRD.
Rodriguez C., Patel A. V., Calle E. E., Jacob E. J., Thun M. J. Estrogen replacement therapy and ovarian cancer mortality in a large prospective study of US women. JAMA. 2001;285(11):1460-5. DES. [pmid: 11255422].
Rodriguez C., Calle E. E., Patel A. V., Tatham L. M., Jacobs E. J., Thun M. J. Effect of body mass on the association between estrogen replacement therapy and mortality among elderly US women. Am J Epidemiol. 2001;153(2):145-52. NRD. [pmid: 11159159].
Rohan T. E., McMichael A. J. Non-contraceptive exogenous oestrogen therapy and breast cancer. Med J Aust. 1988;148(5):217-21. DES. [pmid: 3343950].
Rosano G. M., Vitale C., Silvestri A., Fini M. Hormone replacement therapy and cardioprotection: the end of the tale?. Ann N Y Acad Sci. 2003;997:351-7. NCT. [pmid: 14644842].
Rosenberg L. U., Magnusson C., Lindstrom E., Wedren S., Hall P., Dickman P. W. Menopausal hormone therapy and other breast cancer risk factors in relation to the risk of different histological subtypes of breast cancer: a case-control study. Breast Cancer Res. 2006;8(1):R11. DES. [pmid: 16507159].
Rosenberg L. U., Granath F., Dickman P. W., Einarsdottir K., Wedren S., Persson I., Hall P. Menopausal hormone therapy in relation to breast cancer characteristics and prognosis: a cohort study. Breast Cancer Res. 2008;10(5):R78. DES. [pmid: 18803850].
Ross R. K., Paganini-Hill A., Wan P. C., Pike M. C. Effect of hormone replacement therapy on breast cancer risk: estrogen versus estrogen plus progestin. J Natl Cancer Inst. 2000;92(4):328-32. DES. [pmid: 10675382].
Ross R. K., Paganini-Hill A., Mack T. M., Henderson B. E. Cardiovascular benefits of estrogen replacement therapy. Am J Obstet Gynecol. 1989;160(5 Pt 2):1301-6. NCT. [pmid: 2655453].
Ross R. K., Paganini-Hill A., Gerkins V. R., Mack T. M., Pfeffer R., Arthur M., Henderson B. E. A case-control study of menopausal estrogen therapy and breast cancer. JAMA. 1980;243(16):1635-9. DES. [pmid: 7359751].
Ross S. M. Menopause: a standardized isopropanolic black cohosh extract (remifemin) is found to be safe and effective for menopausal symptoms. Holist Nurs Pract. 2012;26(1):58-61. NCT. [pmid: 22157510].
Ross S. M. Menopause: a standardized isopropanolic black cohosh extract (remifemin) is found to be safe and effective for menopausal symptoms. Holist Nurs Pract. 2012;26(1):58-61. NCT. [pmid: 22157510].
Rossing M. A., Cushing-Haugen K. L., Wicklund K. G., Doherty J. A., Weiss N. S. Menopausal hormone therapy and risk of epithelial ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2007;16(12):2548-56. DES. [pmid: 18086757].
Rossouw J. E., Anderson G. L., Prentice R. L., LaCroix A. Z., Kooperberg C., Stefanick M. L., Jackson R. D., Beresford S. A., Howard B. V., Johnson K. C., Kotchen J. M., Ockene J. Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results From the Women's Health Initiative randomized controlled trial. JAMA. 2002;288(3):321-33. DES. [pmid: 12117397].
Rossouw J. E., Prentice R. L., Manson J. E., Wu L., Barad D., Barnabei V. M., Ko M., LaCroix A. Z., Margolis K. L., Stefanick M. L. Postmenopausal hormone therapy and risk of cardiovascular disease by age and years since menopause. JAMA. 2007;297(13):1465-77. DES. [pmid: 17405972].
Rotem C., Kaplan B. Phyto-Female Complex for the relief of hot flushes, night sweats and quality of sleep: randomized, controlled, double-blind pilot study. Gynecol Endocrinol. 2007;23(2):117-22. NOP. [pmid: 17454163].
Roth M. Y., Amory J. K. Testosterone for low libido in postmenopausal women?. Expert Review of Endocrinology and Metabolism. 2009;4(2):131-133. DUP. [pmid: 22675396].
Rovati L. C., Schmid K., Giacovelli G., Bonn M., Setnikar I., Wolff F., Genazzani A. R. Efficacy on climacteric symptoms of a new estradiol transdermal patch with active matrix in comparison with a reference reservoir patch. Two long-term randomized multicenter parallel-group studies. Arzneimittelforschung. 1999;49(11):933-43. NRC. [pmid: 10604047].
Rowan J. P., Simon J. A., Speroff L., Ellman H. Effects of low-dose norethindrone acetate plus ethinyl estradiol (0.5 mg/2.5 microg) in women with postmenopausal symptoms: updated analysis of three randomized, controlled trials. Clin Ther. 2006;28(6):921-32. NRD. [pmid: 16860174].
Roy J. A., Sawka C. A., Pritchard K. I. Hormone replacement therapy in women with breast cancer. Do the risks outweigh the benefits?. J Clin Oncol. 1996;14(3):997-1006. PTU. [pmid: 8622051].
Rozenbaum H., Birkhauser M., De Nooyer C., Lambotte R., Pornel B., Schneider H., Studd J. Comparison of two estradiol transdermal systems (Oesclim 50 and Estraderm TTS 50). Tolerability I.adhesion and efficacy. Maturitas. 1996;25(3):161-73. NRC. [pmid: 8981333].
Rozenberg S., Caubel P., Lim P. C. Constant estrogen, intermittent progestogen vs. continuous combined hormone replacement therapy: tolerability and effect on vasomotor symptoms. Int J Gynaecol Obstet. 2001;72(3):235-43. NRO. [pmid: 11226444].
Ruan X., Seeger H., Mueck A. O. Breast cancer risk during hormone therapy: experimental versus clinical data. Minerva Endocrinol. 2012;37(1):59-74. NCT. [pmid: 22382615].
Rudic J. S., Poropat G., Krstic M. N., Bjelakovic G., Gluud C. Hormone replacement for osteoporosis in women with primary biliary cirrhosis. Cochrane Database Syst Rev. 2011;12:CD009146. NRP. [pmid: 22161447].
Ruiz A. D., Daniels K. R., Barner J. C., Carson J. J., Frei C. R. Effectiveness of Compounded Bioidentical Hormone Replacement Therapy: An Observational Cohort Study. BMC Women's Health. 2011;11. NRD.
Ruiz A. D., Daniels K. R., Barner J. C., Carson J. J., Frei C. R. Impact of conventional and bioidentical hormone replacement therapy on cardiovascular & breast health: A review. International Journal of Pharmaceutical Compounding. 2011;15(4):290-300. NCT.
Ruiz A., Carson J., Peddaiahgari R., Hummel R. K., Daniels K., Frei C. Bioidentical hormone replacement therapy: An epidemiological study in six community pharmacies. Journal of the American Pharmacists Association. 2010;50(2):222. NRD.
Russo R., Corosu R. The clinical use of a preparation based on phyto-oestrogens in the treatment of menopausal disorders. Acta Biomed. 2003;74(3):137-43. NOP. [pmid: 15055018].
Ryan N., Rosner A. Quality of life and costs associated with micronized progesterone and medroxyprogesterone acetate in hormone replacement therapy for nonhysterectomized, postmenopausal women. Clin Ther. 2001;23(7):1099-115. NRC. [pmid: 11519773].
Ryan-Borchers T., Chew B., Park J. S., McGuire M., Fournier L., Beerman K. Effects of dietary and supplemental forms of isoflavones on thyroid function in healthy postmenopausal women. Topics in Clinical Nutrition. 2008;23(1):13-22. NOP.
Sacks F. M., Lichtenstein A., Van Horn L., Harris W., Kris-Etherton P., Winston M. Soy protein, isoflavones, and cardiovascular health: an American Heart Association Science Advisory for professionals from the Nutrition Committee. Circulation. 2006;113(7):1034-44. NCT. [pmid: 16418439].
Saeki T., Sano M., Komoike Y., Sonoo H., Honjyo H., Ochiai K., Kobayashi T., Aogi K., Sato N., Sawai S., Miyoshi Y., Takeuchi M., Takashima S. No increase of breast cancer incidence in Japanese women who received hormone replacement therapy: overview of a case-control study of breast cancer risk in Japan. Int J Clin Oncol. 2008;13(1):8-11. DES. [pmid: 18307013].
Salagame U., Canfell K., Banks E. An epidemiological overview of the relationship between hormone replacement therapy and breast cancer. Expert Review of Endocrinology and Metabolism. 2011;6(3):397-409. NCT.
Salpeter S. R., Walsh J. M. E., Greyber E., Salpeter E. E. Brief rport: Cronary heart disease events associated with hormone therapy in younger and older women - A meta-analysis. Journal of General Internal Medicine. 2006;21(4):363-366. PTU. [pmid: 16686814].
Salpeter S. R., Walsh J. M., Greyber E., Salpeter E. E. Brief report: Coronary heart disease events associated with hormone therapy in younger and older women. A meta-analysis. J Gen Intern Med. 2006;21(4):363-6. PTU. [pmid: 16686814].
Salpeter S. R., Walsh J. M., Greyber E., Ormiston T. M., Salpeter E. E. Mortality associated with hormone replacement therapy in younger and older women: a meta-analysis. J Gen Intern Med. 2004;19(7):791-804. NRO. [pmid: 15209595].
Samsioe G., Boschitsch E., Concin H., De Geyter C., Ehrenborg A., Heikkinen J., Hobson R., Arguinzoniz M., Ibarra de Palacios P., Scheurer C., Schmidt G. Endometrial safety, overall safety and tolerability of transdermal continuous combined hormone replacement therapy over 96 weeks: a randomized open-label study. Climacteric. 2006;9(5):368-79. DES. [pmid: 17080587].
Sanderson J. E., Haines C. J., Yeung L., Yip G. W., Tang K., Yim S. F., Jorgensen L. N., Woo J. Anti-ischemic action of estrogen-progestogen continuous combined hormone replacement therapy in postmenopausal women with established angina pectoris: a randomized, placebo-controlled, double-blind, parallel-group trial. J Cardiovasc Pharmacol. 2001;38(3):372-83. DES. [pmid: 11486242].
Santen R. J. Risk of breast cancer with progestins: critical assessment of current data. Steroids. 2003;68(10-13):953-64. NCT. [pmid: 14667988].
Santen R. J., Allred D. C., Ardoin S. P., Archer D. F., Boyd N., Braunstein G. D., Burger H. G., Colditz G. A., Davis S. R., Gambacciani M., Gower B. A., Henderson V. W., Jarjour W. N., Karas R. H., Kleerekoper M., Lobo R. A., Manson J. E., Marsden J., Martin K. A., Martin L., Pinkerton J. V., Rubinow D. R., Teede H., Thiboutot D. M., Utian W. H. Postmenopausal hormone therapy: an Endocrine Society scientific statement. J Clin Endocrinol Metab. 2010;95(7 Suppl 1):s1-s66. NCT. [pmid: 20566620].
Santoro N. Symptoms of menopause: hot flushes. Clin Obstet Gynecol. 2008;51(3):539-48. NRD. [pmid: 18677148].
Santoro N., Naftolin F., Black D. M., Brinton E. A., Budoff M. J., Cedars M. I., Dowling N. M., Gleason C. E., Hodis H. N., Lobo R. A., Manson J. E., Merriam G. R., Miller V. M., Neal-Perry G., Pal L., Taylor H. S., Wharton W., Wolff E., Harman S. M. Change over time in menopausal symptoms in women randomized to oral conjugated estrogen or transdermal estradiol plus micronized progesterone versus placebo: The kronos early estrogen prevention study (KEEPS). Menopause. 2012;19(12):1403-1404. NRO.
Sare G. M., Gray L. J., Bath P. M. Association between hormone replacement therapy and subsequent arterial and venous vascular events: a meta-analysis. Eur Heart J. 2008;29(16):2031-41. PTU. [pmid: 18599555].
Sarrel P. M., Njike V. Y., Vinante V., Katz D. L. The mortality toll of estrogen avoidance: an analysis of excess deaths among hysterectomized women aged 50 to 59 years. Am J Public Health. 2013;103:1583-8. DES. [pmid: 23865654].
Saure A., Hirvonen E., Milsom I., Christensen A., Damber M. G. A randomized, double-blind, multicentre study comparing the clinical effects of two sequential estradiol-progestin combinations containing either desogestrel or norethisterone acetate in climacteric women with estrogen deficiency symptoms. Maturitas. 1996;24(1-2):111-8. NRC. [pmid: 8794442].
Savolainen-Peltonen H., Hautamaki H., Tuomikoski P., Ylikorkala O., Mikkola T. S. Health-related quality of life in women with or without hot flashes: A randomized placebo-controlled trial with hormone therapy. Menopause. 2013. NRD.
Saxena T., Lee E., Henderson K. D., Clarke C. A., West D., Marshall S. F., Deapen D., Bernstein L., Ursin G. Menopausal hormone therapy and subsequent risk of specific invasive breast cancer subtypes in the California Teachers Study. Cancer Epidemiol Biomarkers Prev. 2010;19(9):2366-78. DES. [pmid: 20699377].
Scarabin P Y., Oger E., Plu-Bureau G. Differential association of oral and transdermal oestrogen-replacement therapy with venous thromboembolism risk. Lancet. 2003;362(9382):428-32. DES. [pmid: 12927428].
Schairer C., Lubin J., Troisi R., Sturgeon S., Brinton L., Hoover R. Menopausal estrogen and estrogen-progestin replacement therapy and breast cancer risk. JAMA. 2000;283(4):485-91. DES. [pmid: 10659874].
Scharf M. B., Berkowitz D. V., Reape K. Z. Effects of synthetic conjugated estrogens A on sleep quality in postmenopausal women with nocturnal diaphoresis and/or hot flushes: a pilot study. Fertil Steril. 2007;88(3):654-6. NOP. [pmid: 17350629].
Scheele F., Burger C. W., Kenemans P. Postmenopausal hormone replacement in the woman with a reproductive risk factor for breast cancer. Maturitas. 1999;33(3):191-6. PTU. [pmid: 10656497].
Schenck-Gustafsson K., Brincat M., Erel C. T., Gambacciani M., Lambrinoudaki I., Moen M. H., Tremollieres F., Vujovic S., Rozenberg S., Rees M. EMAS position statement: Managing the menopause in the context of coronary heart disease. Maturitas. 2011;68(1):94-7. NCT. [pmid: 21156341].
Schneider C., Jick S. S., Meier C. R. Risk of gynecological cancers in users of estradiol/dydrogesterone or other HRT preparations. Climacteric. 2009;12(6):514-24. DES. [pmid: 19905903].
Schneider C., Jick S. S., Meier C. R. Risk of cardiovascular outcomes in users of estradiol/dydrogesterone or other HRT preparations. Climacteric. 2009;12(5):445-53. DES. [pmid: 19565370].
Schuurman A. G., van den Brandt P. A., Goldbohm R. A. Exogenous hormone use and the risk of postmenopausal breast cancer: results from The Netherlands Cohort Study. Cancer Causes Control. 1995;6(5):416-24. DES. [pmid: 8547539].
Seaman H. E., de Vries C. S., Farmer R. D. The risk of venous thromboembolism in women prescribed cyproterone acetate in combination with ethinyl estradiol: a nested cohort analysis and case-control study. Hum Reprod. 2003;18(3):522-6. DES. [pmid: 12615818].
Secreto G., Chiechi L. M., Amadori A., Miceli R., Venturelli E., Valerio T., Marubini E. Soy isoflavones and melatonin for the relief of climacteric symptoms: a multicenter, double-blind, randomized study. Maturitas. 2004;47(1):11-20. NRP. [pmid: 14706761].
Sellers T. A., Mink P. J., Cerhan J. R., Zheng W., Anderson K. E., Kushi L. H., Folsom A. R. The role of hormone replacement therapy in the risk for breast cancer and total mortality in women with a family history of breast cancer. Ann Intern Med. 1997;127(11):973-80. DES. [pmid: 9412302].
Shah N. R., Borenstein J., Dubois R. W. Postmenopausal hormone therapy and breast cancer: a systematic review and meta-analysis. Menopause. 2005;12(6):668-78. PTU. [pmid: 16278609].
Shams T., Firwana B., Habib F., Alshahrani A., AlNouh B., Murad M. H., Ferwana M. SSRIs for Hot Flashes: A Systematic Review and Meta-Analysis of Randomized Trials. Journal of General Internal Medicine. 2013:1-10. NRD. [pmid: 23242866].
Shams T., Setia M. S., Hemmings R., McCusker J., Sewitch M., Ciampi A. Efficacy of black cohosh-containing preparations on menopausal symptoms: a meta-analysis. Altern Ther Health Med. 2010;16(1):36-44. NRD. [pmid: 20085176].
Shantakumar S., Terry M. B., Paykin A., Teitelbaum S. L., Britton J. A., Moorman P. G., Kritchevsky S. B., Neugut A. I., Gammon M. D. Age and menopausal effects of hormonal birth control and hormone replacement therapy in relation to breast cancer risk. Am J Epidemiol. 2007;165(10):1187-98. DES. [pmid: 17337757].
Shapiro J. A., Weiss N. S., Beresford S. A., Voigt L. F. Menopausal hormone use and endometrial cancer, by tumor grade and invasion. Epidemiology. 1998;9(1):99-101. DES. [pmid: 9430277].
Shapiro S. Recent epidemiological evidence relevant to the clinical management of the menopause. Climacteric. Suppl 2. 2007;10:2-15. NRD. [pmid: 17882666].
Shapiro S. Risks of estrogen plus progestin therapy: a sensitivity analysis of findings in the Women's Health Initiative randomized controlled trial. Climacteric. 2003;6(4):302-10. discussion 310-3. DES. [pmid: 15006251].
Shapiro S., Farmer R. D., Mueck A. O., Seaman H., Stevenson J. C. Does hormone replacement therapy cause breast cancer? An application of causal principles to three studies: part 3. The Women's Health Initiative: unopposed estrogen. J Fam Plann Reprod Health Care. 2011;37(4):225-30. DES. [pmid: 21642263].
Shapiro S., Farmer R. D. T., Mueck A. O., Seaman H., Stevenson J. C. Does hormone replacement therapy cause breast cancer? An application of causal principles to three studies. Part 2. The Women's Health Initiative: Estrogen plus progestogen. Journal of Family Planning and Reproductive Health Care. 2011;37(3):165-172. DES. [pmid: 21642264].
Sharma S. Hormone Replacement Therapy in menopause: current concerns and considerations. Kathmandu Univ Med J (KUMJ). 2003;1(4):288-93. NCT. [pmid: 16388273].
Shen W., Stearns V. Treatment strategies for hot flushes. Expert Opin Pharmacother. 2009;10(7):1133-44. NRD. [pmid: 19405789].
Shepherd J. E. Effects of estrogen on congnition mood, and degenerative brain diseases. J Am Pharm Assoc (Wash). 2001;41(2):221-8. NRD. [pmid: 11297335].
Shergis J. L., Zhang A. L., Zhou W., Xue C. C. Panax ginseng in Randomised Controlled Trials: A Systematic Review. Phytother Res. 2012. NRD.
Sherman A. M., Shumaker S. A., Sharp P., Reboussin D. M., Kancler C., Walkup M., Herrington D. M. No effect of HRT on health-related quality of life in postmenopausal women with heart disease. Minerva Ginecol. 2003;55(6):511-7. NRP. [pmid: 14676740].
Sherman B., Wallace R., Bean J. Estrogen use and breast cancer. Interaction with body mass. Cancer. 1983;51(8):1527-31. DES. [pmid: 6825058].
Sherman S., Miller H., Nerurkar L., Schiff I. Research opportunities for reducing the burden of menopause-related symptoms. Am J Med. Suppl 12B. 2005;118:166-71. NRQ. [pmid: 16414344].
Sherwin B. B. Randomized clinical trials of combined estrogen-androgen preparations: effects on sexual functioning. Fertil Steril. Suppl 4. 2002;77:S49-54. NRD. [pmid: 12007902].
Sherwin B. B. Estrogen and mood in women. Endocrinologist. 2005;15(3):180-185. NCT.
Sherwin B. B., Gelfand M. M. Sex steroids and affect in the surgical menopause: a double-blind, cross-over study. Psychoneuroendocrinology. 1985;10(3):325-35. NOP. [pmid: 3903822].
Sherwin B. B., Gelfand M. M. Differential symptom response to parenteral estrogen and/or androgen administration in the surgical menopause. Am J Obstet Gynecol. 1985;151(2):153-60. NOP. [pmid: 3881960].
Sherwin B. B., Gelfand M. M., Brender W. Androgen enhances sexual motivation in females: a prospective, crossover study of sex steroid administration in the surgical menopause. Psychosom Med. 1985;47(4):339-51. NOP. [pmid: 4023162].
Shetty K. D., Vogt W. B., Bhattacharya J. Hormone replacement therapy and cardiovascular health in the United States. Med Care. 2009;47(5):600-6. DES. [pmid: 19319001].
Shifren J. L., Braunstein G. D., Simon J. A., Casson P. R., Buster J. E., Redmond G. P., Burki R. E., Ginsburg E. S., Rosen R. C., Leiblum S. R., Caramelli K. E., Mazer N. A. Transdermal testosterone treatment in women with impaired sexual function after oophorectomy. N Engl J Med. 2000;343(10):682-8. NOP. [pmid: 10974131].
Shin B. C., Lee M. S., Yang E. J., Lim H. S., Ernst E. Maca (L. meyenii) for improving sexual function: a systematic review. BMC Complement Altern Med. 2010;10:44. NRD. [pmid: 20691074].
Shlipak M. G., Elmouchi D. A., Herrington D. M., Lin F., Grady D., Hlatky M. A. The incidence of unrecognized myocardial infarction in women with coronary heart disease. Ann Intern Med. 2001;134(11):1043-7. DES. [pmid: 11388817].
Shou C., Li J., Liu Z. Complementary and alternative medicine in the treatment of menopausal symptoms. Chin J Integr Med. 2011;17(12):883-8. NRD. [pmid: 22139538].
Shulman L. P. The adverse impact of hormone therapy discontinuation on bone health: Initiating a more balanced and comprehensive assessment of the impact and role of postmenopausal hormone therapy. Menopause. 2011;18(11):1152-1153. NRQ. [pmid: 22033486].
Shulman L. P., Yankov V., Uhl K. Safety and efficacy of a continuous once-a-week 17beta-estradiol/levonorgestrel transdermal system and its effects on vasomotor symptoms and endometrial safety in postmenopausal women: the results of two multicenter, double-blind, randomized, controlled trials. Menopause. 2002;9(3):195-207. NRC. [pmid: 11973443].
Sicat B. L. Should postmenopausal hormone therapy be used to prevent osteoporosis?. Consultant Pharmacist. 2004;19(8):725-735. PTU. [pmid: 16553495].
Signorelli S. S., Sciacchitano S., Anzaldi M., Fiore V., Catanzaro S., Simili M., Neri S. Effects of long-term hormone replacement therapy: results from a cohort study. J Endocrinol Invest. 2011;34(3):180-4. DES. [pmid: 20414045].
Sillero-Arenas M., Delgado-Rodriguez M., Rodigues-Canteras R., Bueno-Cavanillas A., Galvez-Vargas R. Menopausal hormone replacement therapy and breast cancer: a meta-analysis. Obstet Gynecol. 1992;79(2):286-94. PTU. [pmid: 1530988].
Sim L. A., McGovern L., Elamin M. B., Swiglo B. A., Erwin P. J., Montori V. M. Effect on bone health of estrogen preparations in premenopausal women with anorexia nervosa: a systematic review and meta-analyses. Int J Eat Disord. 2010;43(3):218-25. NRO. [pmid: 19350651].
Simon J. A. What's new in hormone replacement therapy: Focus on transdermal estradiol and micronized progesterone. Climacteric. 2012;15(SUPPL.1):3-10. NCT. [pmid: 22432810].
Simon J. A., Hunninghake D. B., Agarwal S. K., Lin F., Cauley J. A., Ireland C. C., Pickar J. H. Effect of estrogen plus progestin on risk for biliary tract surgery in postmenopausal women with coronary artery disease. The Heart and Estrogen/progestin Replacement Study. Ann Intern Med. 2001;135(7):493-501. DES. [pmid: 11578152].
Simon J. A., Lin F., Vittinghoff E., Bittner V. The relation of postmenopausal hormone therapy to serum uric acid and the risk of coronary heart disease events: the Heart and Estrogen-Progestin Replacement Study (HERS). Ann Epidemiol. 2006;16(2):138-45. DES. [pmid: 16039873].
Simon J. A., Nahum G. G., Stanislaw H., Gaines T. The breast cancer "plunge" after initial publication of the WHI results: an alternative explanation. Maturitas. 2010;66(3):277-84. DES. [pmid: 20471761].
Simon J. A., Sanacora G., Bhaskar S., Lippman J. Safety and efficacy of low-dose mesylate salt of paroxetine (LDMP) for the treatment of vasomotor symptoms (VMS) associated with menopause: A 24-week, randomized, placebo-controlled phase 3 study. Menopause. 2012;19(12):1371. DUP.
Simon J. A., Hsia J., Cauley J. A., Richards C., Harris F., Fong J., Barrett-Connor E., Hulley S. B. Postmenopausal hormone therapy and risk of stroke: The Heart and Estrogen-progestin Replacement Study (HERS). Circulation. 2001;103(5):638-42. DES. [pmid: 11156873].
Simon J. A., Reape K. Z., Wininger S., Hait H. Randomized, multicenter, double-blind, placebo-controlled trial to evaluate the efficacy and safety of synthetic conjugated estrogens B for the treatment of vulvovaginal atrophy in healthy postmenopausal women. Fertil Steril. 2008;90(4):1132-8. NRO. [pmid: 18053998].
Simon J., Klaiber E., Wiita B., Bowen A., Yang H. M. Differential effects of estrogen-androgen and estrogen-only therapy on vasomotor symptoms, gonadotropin secretion, and endogenous androgen bioavailability in postmenopausal women. Menopause. 1999;6(2):138-46. NOP. [pmid: 10374221].
Simon J., Nachtigall L., Ulrich L. G., Eugster-Hausmann M., Gut R. Endometrial safety of ultra-low-dose estradiol vaginal tablets. Obstet Gynecol. 2010;116(4):876-83. DES. [pmid: 20859151].
Simon J., Nachtigall L., Gut R., Lang E., Archer D. F., Utian W. Effective treatment of vaginal atrophy with an ultra-low-dose estradiol vaginal tablet. Obstet Gynecol. 2008;112(5):1053-60. NRO. [pmid: 18978105].
Simoncini T., Genazzani A. R. A review of the cardiovascular and breast actions of drospirenone in preclinical studies. Climacteric. 2010;13(1):22-33. NCT. [pmid: 19938948].
Skouby S. O., Al-Azzawi F., Barlow D., Calaf-Alsina Erdogan Ertungealp J., Gompel A., Graziottin A., Hudita D., Pines A., Rozenberg S., Samsioe G., Stevenson J. C. Climacteric medicine: European Menopause and Andropause Society (EMAS) 2004/2005 position statements on peri- and postmenopausal hormone replacement therapy. Maturitas. 2005;51(1):8-14. NCT. [pmid: 15883103].
Slanger T. E., Chang-Claude J. C., Obi N., Kropp S., Berger J., Vettorazzi E., Braendle W., Bastert G., Hentschel S., Flesch-Janys D. Menopausal hormone therapy and risk of clinical breast cancer subtypes. Cancer Epidemiol Biomarkers Prev. 2009;18(4):1188-96. DES. [pmid: 19336542].
Smith N. L., Heckbert S. R., Lemaitre R. N., Reiner A. P., Lumley T., Rosendaal F. R., Psaty B. M. Conjugated equine estrogen, esterified estrogen, prothrombotic variants, and the risk of venous thrombosis in postmenopausal women. Arterioscler Thromb Vasc Biol. 2006;26(12):2807-12. DES. [pmid: 16973976].
Smith N. L., Heckbert S. R., Lemaitre R. N., Reiner A. P., Lumley T., Weiss N. S., Larson E. B., Rosendaal F. R., Psaty B. M. Esterified estrogens and conjugated equine estrogens and the risk of venous thrombosis. JAMA. 2004;292(13):1581-7. DES. [pmid: 15467060].
Snabes M. C., Zborowski J., Simes S. Libigel(registered trademark) (testosterone gel) does not differentiate from placebo therapy in the treatment of hypoactive sexual desire disorder in postmenopausal women. Journal of Sexual Medicine. 2012;9:171. NOP.
Snabes M., Connor J., Berry D., Zborowski J., White W. Low cardiovascular event rate in post-menopausal women with increased cardiac risk: Findings from the ongoing blinded libigel(registered trademark) (Testosterone Gel) cardiovascular and breast cancer safety study. Reproductive Sciences. 2010;17(3):269A. DES. [pmid: 20124553].
Soares C. N. Escitalopram reduced hot flashes in non-depressed perimenopausal and postmenopausal women. Evidence-Based Medicine. 2011;16(5):159-160. NRD. [pmid: 21561928].
Soares C. N. Escitalopram reduced hot flashes in non-depressed perimenopausal and postmenopausal women. Evidence-Based Medicine. 2011;16(5):159-160. NCT. [pmid: 21561928].
Soares C. N., Joffe H., Rubens R., Caron J., Roth T., Cohen L. Eszopiclone in patients with insomnia during perimenopause and early postmenopause: a randomized controlled trial. Obstet Gynecol. 2006;108(6):1402-10. NRF. [pmid: 17138773].
Soares C. N., Thase M. E., Clayton A., Guico-Pabia C. J., Focht K., Jiang Q., Kornstein S. G., Ninan P. T., Kane C. P. Open-label treatment with desvenlafaxine in postmenopausal women with major depressive disorder not responding to acute treatment with desvenlafaxine or escitalopram. CNS Drugs. 2011;25(3):227-38. NRF. [pmid: 21323394].
Somboonporn W., Davis S. R. Postmenopausal testosterone therapy and breast cancer risk. Maturitas. 2004;49(4):267-75. NCT. [pmid: 15531122].
Somboonporn W., Davis S., Seif M. W., Bell R. Testosterone for peri- and postmenopausal women. Cochrane Database Syst Rev. 2005;(4):CD004509. NRD. [pmid: 16235365].
Somboonporn W., Panna S., Temtanakitpaisan T., Kaewrudee S., Soontrapa S. Effects of the levonorgestrel-releasing intrauterine system plus estrogen therapy in perimenopausal and postmenopausal women: systematic review and meta-analysis. Menopause. 2011. NRD.
Soy, black cohosh may have some benefit for menopause symptoms. Journal of Family Practice. 2006;55(11):939. NRD. [pmid: 17115484].
Spark M. J., Willis J. Systematic review of progesterone use by midlife and menopausal women. Maturitas. 2012;72(3):192-202. NRD. [pmid: 22541358].
Spector T. D., Brennan P., Harris P. A., Studd J. W., Silman A. J. Do current regimes of hormone replacement therapy protect against subsequent fractures?. Osteoporos Int. 1992;2(5):219-24. DES. [pmid: 1392259].
Spengler R. F., Clarke E. A., Woolever C. A., Newman A. M., Osborn R. W. Exogenous estrogens and endometrial cancer: a case-control study and assessment of potential biases. Am J Epidemiol. 1981;114(4):497-506. DES. [pmid: 7304580].
Sprague B. L., Trentham-Dietz A., Egan K. M., Titus-Ernstoff L., Hampton J. M., Newcomb P. A. Proportion of invasive breast cancer attributable to risk factors modifiable after menopause. Am J Epidemiol. 2008;168(4):404-11. DES. [pmid: 18552361].
van Staa T. P., Cooper C., Barlow D., Leufkens H. G. Individualizing the risks and benefits of postmenopausal hormone therapy. Menopause. 2008;15(2):374-81. DES. [pmid: 17882009].
Staffa J. A., Newschaffer C. J., Jones J. K., Miller V. Progestins and breast cancer: an epidemiologic review. Fertil Steril. 1992;57(3):473-91. NRQ. [pmid: 1740192].
Stahlberg C., Pedersen A. T., Lynge E., Andersen Z. J., Keiding N., Hundrup Y. A., Obel E. B., Ottesen B. Increased risk of breast cancer following different regimens of hormone replacement therapy frequently used in Europe. Int J Cancer. 2004;109(5):721-7. DES. [pmid: 14999781].
Stahlberg C., Pedersen A. T., Andersen Z. J., Keiding N., Hundrup Y. A., Obel E. B., Moller S., Rank F., Ottesen B., Lynge E. Breast cancer with different prognostic characteristics developing in Danish women using hormone replacement therapy. Br J Cancer. 2004;91(4):644-50. DES. [pmid: 15238982].
Stampfer M. J., Colditz G. A. Estrogen replacement therapy and coronary heart disease: a quantitative assessment of the epidemiologic evidence. Prev Med. 1991;20(1):47-63. PTU. [pmid: 1826173].
Stanford J. L., Brinton L. A., Berman M. L., Mortel R., Twiggs L. B., Barrett R. J., Wilbanks G. D., Hoover R. N. Oral contraceptives and endometrial cancer: do other risk factors modify the association?. Int J Cancer. 1993;54(2):243-8. DES. [pmid: 8486426].
Stanford J. L., Weiss N. S., Voigt L. F., Daling J. R., Habel L. A., Rossing M. A. Combined estrogen and progestin hormone replacement therapy in relation to risk of breast cancer in middle-aged women. JAMA. 1995;274(2):137-42. DES. [pmid: 7596001].
Staren E. D., Omer S. Hormone replacement therapy in postmenopausal women. Am J Surg. 2004;188(2):136-49. NCT. [pmid: 15249239].
Stefanick M. L. Postmenopausal hormone therapy and cardiovascular disease in women. Nutr Metab Cardiovasc Dis. 2010;20(6):451-8. NCT. [pmid: 20554177].
Stefanick M. L., Anderson G. L., Margolis K. L., Hendrix S. L., Rodabough R. J., Paskett E. D., Lane D. S., Hubbell F. A., Assaf A. R., Sarto G. E., Schenken R. S., Yasmeen S., Lessin L., Chlebowski R. T. Effects of conjugated equine estrogens on breast cancer and mammography screening in postmenopausal women with hysterectomy. JAMA. 2006;295(14):1647-57. DES. [pmid: 16609086].
Steinberg F. M., Murray M. J., Lewis R. D., Cramer M. A., Amato P., Young R. L., Barnes S., Konzelmann K. L., Fischer J. G., Ellis K. J., Shypailo R. J., Fraley J. K., Smith E. O., Wong W. W. Clinical outcomes of a 2-y soy isoflavone supplementation in menopausal women. Am J Clin Nutr. 2011;93(2):356-67. NRO. [pmid: 21177797].
Steinberg K. K., Thacker S. B., Smith S. J., Stroup D. F., Zack M. M., Flanders W. D., Berkelman R. L. A meta-analysis of the effect of estrogen replacement therapy on the risk of breast cancer. JAMA. 1991;265(15):1985-90. PTU. [pmid: 1826136].
Steinberg K. Duration/dose of HRT and risk of breast cancer in the unselected populations: Data from meta-analysis. Obstetrical and Gynecological Survey. 1998;53(10 SUPPL.):S13-S16. PTU.
Steingart A., Cotterchio M., Kreiger N., Sloan M. Antidepressant medication use and breast cancer risk: a case-control study. Int J Epidemiol. 2003;32(6):961-6. NRP. [pmid: 14681256].
Steingold K. A., Laufer L., Chetkowski R. J., DeFazio J. D., Matt D. W., Meldrum D. R., Judd H. L. Treatment of hot flashes with transdermal estradiol administration. J Clin Endocrinol Metab. 1985;61(4):627-32. NOP. [pmid: 3928674].
Stevens R. E., Hanford K., Wason S., Cusack S. L., Phelps K. V. A 12-week clinical trial determining the efficacy of synthetic conjugated estrogens, A (SCE), in the treatment of vasomotor symptoms in menopausal women. Int J Fertil Womens Med. 2000;45(4):264-72. DUP. [pmid: 10997482].
Stevenson J. C., Panay N., Pexman-Fieth C. Oral estradiol and dydrogesterone combination therapy in postmenopausal women: Review of efficacy and safety. Maturitas. 2013;76:10-21. NRD. [pmid: 23835005].
Stevenson J. C., Hodis H. N., Pickar J. H., Lobo R. A. HRT and breast cancer risk: A realistic perspective. Climacteric. 2011;14(6):633-636. DES. [pmid: 21864135].
Stevenson J. C., Hodis H. N., Pickar J. H., Lobo R. A. HRT and breast cancer risk: a realistic perspective. Climacteric. 2011;14(6):633-6. NCT. [pmid: 21864135].
Straczek C., Oger E., Yon de Jonage-Canonico M. B., Plu-Bureau G., Conard J., Meyer G., Alhenc-Gelas M., Levesque H., Trillot N., Barrellier M. T., Wahl D., Emmerich J., Scarabin P. Y. Prothrombotic mutations, hormone therapy, and venous thromboembolism among postmenopausal women: impact of the route of estrogen administration. Circulation. 2005;112(22):3495-500. DES. [pmid: 16301339].
Stram D. O., Liu Y., Henderson K. D., Sullivan-Halley J., Luo J., Saxena T., Reynolds P., Chang E. T., Neuhausen S. L., Horn-Ross P. L., Bernstein L., Ursin G. Age-specific effects of hormone therapy use on overall mortality and ischemic heart disease mortality among women in the California Teachers Study. Menopause. 2011;18(3):253-61. DES. [pmid: 20881652].
Strom B. L., Schinnar R., Weber A. L., Bunin G., Berlin J. A., Baumgarten M., DeMichele A., Rubin S. C., Berlin M., Troxel A. B., Rebbeck T. R. Case-control study of postmenopausal hormone replacement therapy and endometrial cancer. Am J Epidemiol. 2006;164(8):775-86. DES. [pmid: 16997897].
Study Evaluating The Safety And Efficacy Of Desvenlafaxine Succinate For Vasomotor Symptoms In Menopausal Women. NCT00683800. 2011. DUP.
Sturdee D. W. The menopausal hot flush--anything new?. Maturitas. 2008;60(1):42-9. NRQ. [pmid: 18384981].
Su I. H., Chen Y. C., Hwang W. T., Liu Z., Su T. P., Chen T. J., Barnhart K. T., Yang Y. X. Risks and benefits of menopausal hormone therapy in postmenopausal Chinese women. Menopause. 2012;19(8):931-941. NCT. [pmid: 22453198].
Suckling J., Lethaby A., Kennedy R. Local oestrogen for vaginal atrophy in postmenopausal women. Cochrane Database Syst Rev. 2006;(4):CD001500. NRD. [pmid: 17054136].
Sulak P. J., Caubel P., Lane R. Efficacy and safety of a constant-estrogen, pulsed-progestin regimen in hormone replacement therapy. Int J Fertil Womens Med. 1999;44(6):286-96. NRO. [pmid: 10617250].
Sullivan J. M. Hormone replacement in the secondary prevention of cardiovascular disease. Cardiovascular Risk Factors. 1996;6(2):94-98. DES.
Sullivan J. M., Vander Zwaag R., Lemp G. F., Hughes J. P., Maddock V., Kroetz F. W., Ramanathan K. B., Mirvis D. M. Postmenopausal estrogen use and coronary atherosclerosis. Ann Intern Med. 1988;108(3):358-63. DES. [pmid: 3341672].
Sun Z., Hao Y., Zhang M. Efficacy and safety of desvenlafaxine treatment for hot flashes associated with menopause: A meta-analysis of randomized controlled trials. Gynecologic and Obstetric Investigation. 2013;75(4):255-262. NRD. [pmid: 23548358].
Taku K., Melby M. K., Kronenberg F., Kurzer M. S., Messina M. Extracted or synthesized soybean isoflavones reduce menopausal hot flash frequency and severity: systematic review and meta-analysis of randomized controlled trials. Menopause. 2012;19(7):776-90. NRD. [pmid: 22433977].
Talamini R., Franceschi S., Dal Maso L., Negri E., Conti E., Filiberti R., Montella M., Nanni O., La Vecchia C. The influence of reproductive and hormonal factors on the risk of colon and rectal cancer in women. Eur J Cancer. 1998;34(7):1070-6. DES. [pmid: 9849456].
Tamimi R. M., Hankinson S. E., Chen W. Y., Rosner B., Colditz G. A. Combined estrogen and testosterone use and risk of breast cancer in postmenopausal women. Arch Intern Med. 2006;166(14):1483-9. DES. [pmid: 16864758].
Tamler R., Mechanick J. I. Dietary supplements and nutraceuticals in the management of endocrine disorders. Current Opinion in Endocrinology and Diabetes. 2006;13(5):425-430. NRD.
Tan D., Haines C. J., Limpaphayom K. K., Holinka C. F., Ausmanas M. K. Relief of vasomotor symptoms and vaginal atrophy with three doses of conjugated estrogens and medroxyprogesterone acetate in postmenopausal Asian women from 11 countries: The Pan-Asia menopause (PAM) study. Maturitas. 2005;52(1):35-51. DUP. [pmid: 16211697].
Tanaka S., Matsuyama Y., Shiraki M., Ohashi Y. Estimating the effects of time-varying treatments: incidence of fractures among postmenopausal Japanese women. Epidemiology. 2007;18(5):529-36. DES. [pmid: 17700241].
Tavani A., Braga C., La Vecchia C., Negri E., Franceschi S. Hormone replacement treatment and breast cancer risk: an age-specific analysis. Cancer Epidemiol Biomarkers Prev. 1997;6(1):11-4. DES. [pmid: 8993791].
Tavani A., Negri E., La Vecchia C. Menstrual and reproductive factors and biliary tract cancers. Eur J Cancer Prev. 1996;5(4):241-7. DES. [pmid: 8894561].
Taylor H. S., Harman S. M., Pal L., Minkin M. J., Wolff E., Black D., Brinton E., Budoff M., Cedars M., Hodis H., Lobo R., Manson J. E., Merriam G., Miller V. M., Naftolin F., Neal-Perry G., Santoro N. Effects of oral vs transdermal estrogen vs placebo on sexual function over time in the kronos early estrogen prevention study (KEEPS). Menopause. 2012;19(12):1373-1374. NRO.
Teede H. J. Controversies in HRT. Aust Fam Physician. 2002;31(5):413-8. NCT. [pmid: 12043543].
Tempfer C. B., Bentz E. K., Leodolter S., Tscherne G., Reuss F., Cross H. S., Huber J. C. Phytoestrogens in clinical practice: a review of the literature. Fertil Steril. 2007;87(6):1243-9. NRD. [pmid: 17490659].
Tengstrand B. Oestrogen plus progestin significantly improves bone mineral density and reduces risk of fracture. Evidence-Based Healthcare. 2004;8(2):102-104. DES.
Tesch B. J. Herbs commonly used by women: an evidence-based review. Dis Mon. 2002;48(10):671-96. NCT. [pmid: 12562054].
Teschke R. Black cohosh and suspected hepatotoxicity: inconsistencies, confounding variables, and prospective use of a diagnostic causality algorithm. A critical review. Menopause. 2010;17(2):426-40. NRP. [pmid: 20216279].
Thacker H. L. Assessing risks and benefits of nonhormonal treatments for vasomotor symptoms in perimenopausal and postmenopausal women. Journal of Women's Health. 2011;20(7):1007-1016. NRD.
A randomized study to compare the effectiveness, tolerability, and acceptability of two different transdermal estradiol replacement therapies. The Transdermal HRT Investigators Group. Int J Fertil Menopausal Stud. 1993;38(1):5-11. NRC. [pmid: 8485612].
The role of isoflavones in menopausal health: consensus opinion of The North American Menopause Society. Menopause. 2000;7(4):215-29. NCT. [pmid: 10914614].
The role of testosterone therapy in postmenopausal women: position statement of The North American Menopause Society. Menopause. 2005;12(5):496-511. quiz 649. NRD. [pmid: 16145303].
The role of local vaginal estrogen for treatment of vaginal atrophy in postmenopausal women: 2007 position statement of The North American Menopause Society. Menopause. 2007;14(3 Pt 1):355-69. quiz 370-1. NRD. [pmid: 17438512].
Thomas D. B. Oral contraceptives and breast cancer: review of the epidemiologic literature. Contraception. 1991;43(6):597-642. NRQ. [pmid: 1868735].
Thompson E. A. Alternative and complementary therapies for the menopause: a homeopathic approach. Maturitas. 2010;66(4):350-4. NRD. [pmid: 20207087].
Tjonneland A., Christensen J., Thomsen B. L., Olsen A., Overvad K., Ewertz M., Mellemkjaer L. Hormone replacement therapy in relation to breast carcinoma incidence rate ratios: a prospective Danish cohort study. Cancer. 2004;100(11):2328-37. DES. [pmid: 15160335].
Toh S., Manson J. E. An Analytic Framework for Aligning Observational and Randomized Trial Data: Application to Postmenopausal Hormone Therapy and Coronary Heart Disease. Statistics in Biosciences. 2013;5:344-360. DES.
Toh S., Hernandez-Diaz S., Logan R., Rossouw J. E., Hernan M. A. Coronary heart disease in postmenopausal recipients of estrogen plus progestin therapy: does the increased risk ever disappear? A randomized trial. Ann Intern Med. 2010;152(4):211-7. DES. [pmid: 20157135].
Toles C. A. The incidence of cardiovascular disease in menopausal women on hormone replacement therapy: a clinical evidence-based medicine review. J Natl Black Nurses Assoc. 2007;18(2):75-80. PTU. [pmid: 18318334].
Toulis K. A., Tzellos T., Kouvelas D., Goulis D. G. Gabapentin for the treatment of hot flashes in women with natural or tamoxifen-induced menopause: a systematic review and meta-analysis. Clin Ther. 2009;31(2):221-35. NRD. [pmid: 19302896].
Toulis K., Tzellos T., Kouvelas D., Sardeli C., Papazisis G., Chourdakis M., Goulis D. Safety and tolerability of (alpha)2(delta) ligand gabapentin in treating hot flashes: An evidence-based systematic review and meta-analysis. Review of Clinical Pharmacology and Pharmacokinetics, International Edition. 2010;24(2):227-228. NRD.
Treatment of menopause-associated vasomotor symptoms: position statement of The North American Menopause Society. Menopause. 2004;11(1):11-33. NRD. [pmid: 14716179].
Trock B. J., Hilakivi-Clarke L., Clarke R. Meta-analysis of soy intake and breast cancer risk. J Natl Cancer Inst. 2006;98(7):459-71. NRP. [pmid: 16595782].
Tuomikoski P., Mikkola T. S., Tikkanen M. J., Ylikorkala O. Hot flushes and biochemical markers for cardiovascular disease: a randomized trial on hormone therapy. Climacteric. 2010;13(5):457-66. NRQ. [pmid: 20443719].
Tworoger S. S., Missmer S. A., Barbieri R. L., Willett W. C., Colditz G. A., Hankinson S. E. Plasma sex hormone concentrations and subsequent risk of breast cancer among women using postmenopausal hormones. J Natl Cancer Inst. 2005;97(8):595-602. DES. [pmid: 15840882].
Udoff L., Langenberg P., Adashi E. Y. Combined continuous hormone replacement therapy: a critical review. Obstet Gynecol. 1995;86(2):306-16. NRD. [pmid: 7617369].
Uhler M. L., Marks J. W., Judd H. L. Estrogen replacement therapy and gallbladder disease in postmenopausal women. Menopause. 2000;7(3):162-7. NRO. [pmid: 10810961].
Umland E. M., Rinaldi C., Parks S. M., Boyce E. G. The impact of estrogen replacement therapy and raloxifene on osteoporosis, cardiovascular disease, and gynecologic cancers. Ann Pharmacother. 1999;33(12):1315-28. NRO. [pmid: 10630832].
Unfer V., Casini M. L., Costabile L., Mignosa M., Gerli S., Di Renzo G. C. Endometrial effects of long-term treatment with phytoestrogens: a randomized, double-blind, placebo-controlled study. Fertil Steril. 2004;82(1):145-8. quiz 265. DES. [pmid: 15237003].
Ursin G., Tseng C. C., Paganini-Hill A., Enger S., Wan P. C., Formenti S., Pike M. C., Ross R. K. Does menopausal hormone replacement therapy interact with known factors to increase risk of breast cancer?. J Clin Oncol. 2002;20(3):699-706. DES. [pmid: 11821451].
Ushiroyama T., Ikeda A., Ueki M. Evaluation of double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients in menopause transition. J Med. 2004;35(1-6):151-62. NRP. [pmid: 18084873].
Utian W. H. Recent Developments in Pharmacotherapy for Vasomotor Symptoms. Current Obstetrics and Gynecology Reports. 2012;1(2):43-49. NRD.
UtianW W. H. The true clincal features of postmenopause and oophorectomy, and their response to oestrogen therapy. S Afr Med J. 1972;46(23):732-7. NOP. [pmid: 4561677].
Utian W. H., Gass M. L., Pickar J. H. Body mass index does not influence response to treatment, nor does body weight change with lower doses of conjugated estrogens and medroxyprogesterone acetate in early postmenopausal women. Menopause. 2004;11(3):306-14. NRO. [pmid: 15167310].
Vakil D. V., Morgan R. W., Halliday M. Exogenous estrogens and development of breast and endometrial cancer. Cancer Detect Prev. 1983;6(4-5):415-24. DES. [pmid: 6652636].
Valdiviezo C., Lawson S., Ouyang P. An update on menopausal hormone replacement therapy in women and cardiovascular disease. Current Opinion in Endocrinology, Diabetes and Obesity. 2013;20(2):148-155. NCT.
Van Leusden H. A., Albertyn G., Verlaine C., Van Ruymbeke J. A comparative multicenter study of two transdermal estradiol replacement therapies in the treatment of postmenopausal symptoms. Int J Fertil Menopausal Stud. 1993;38(4):210-8. NRC. [pmid: 8401679].
Van De Weijer P. H. M. Long-term adherence to continuous combined HRT: Seven-year update on the Heikkinen study. Journal of the British Menopause Society. 2003;9(SUPPL. 1):8-9. NRO.
Veerus P., Hovi S. L., Fischer K., Rahu M., Hakama M., Hemminki E. Results from the Estonian postmenopausal hormone therapy trial [ISRCTN35338757]. Maturitas. 2006;55(2):162-73. DES. [pmid: 16504428].
Vega V. Cardioprotective benefits of hormone replacement therapy. J Am Acad Nurse Pract. 2001;13(2):69-76. quiz 77-9. PTU. [pmid: 11930400].
Velentzis L. S., Cantwell M. M., Cardwell C., Keshtgar M. R., Leathem A. J., Woodside J. V. Lignans and breast cancer risk in pre- and post-menopausal women: meta-analyses of observational studies. Br J Cancer. 2009;100(9):1492-8. NRP. [pmid: 19337250].
Vestergaard P. Postmenopausal hormone therapy. Current Women's Health Reviews. 2006;2(4):197-205. DES.
Vestergaard P., Mosekilde L., Langdahl B. Fracture prevention in postmenopausal women. Clin Evid (Online) 2011. 2011. PTU.
Vestergaard P., Hermann P., Jensen J. E. B., Eiken P., Mosekilde L. Effects of paracetamol, non-steroidal anti-inflammatory drugs, acetylsalicylic acid, and opioids on bone mineral density and risk of fracture: Results of the Danish Osteoporosis Prevention Study (DOPS). Osteoporosis International. 2012;23(4):1255-1265. NRC. [pmid: 21710339].
Vickers M. R., MacLennan A. H., Lawton B., Ford D., Martin J., Meredith S. K., DeStavola B. L., Rose S., Dowell A., Wilkes H. C., Darbyshire J. H., Meade T. W. Main morbidities recorded in the women's international study of long duration oestrogen after menopause (WISDOM): a randomised controlled trial of hormone replacement therapy in postmenopausal women. BMJ. 2007;335(7613):239. DES. [pmid: 17626056].
Villaseca P. Non-estrogen conventional and phytochemical treatments for vasomotor symptoms: what needs to be known for practice. Climacteric. 2012;15(2):115-24. NRD. [pmid: 22148909].
Vincent A., Fitzpatrick L. A. Soy isoflavones: are they useful in menopause?. Mayo Clin Proc. 2000;75(11):1174-84. NRD. [pmid: 11075748].
Viscoli C. M., Brass L. M., Kernan W. N., Sarrel P. M., Suissa S., Horwitz R. I. A clinical trial of estrogen-replacement therapy after ischemic stroke. N Engl J Med. 2001;345(17):1243-9. DES. [pmid: 11680444].
Viscoli C. M., Brass L. M., Kernan W. N., Sarrel P. M., Suissa S., Horwitz R. I. Estrogen therapy and risk of cognitive decline: results from the Women's Estrogen for Stroke Trial (WEST). Am J Obstet Gynecol. 2005;192(2):387-93. DES. [pmid: 15695976].
Voigt L. F., Weiss N. S., Chu J., Daling J. R., McKnight B., van Belle G. Progestagen supplementation of exogenous oestrogens and risk of endometrial cancer. Lancet. 1991;338(8762):274-7. DES. [pmid: 1677110].
Voigt L. F., Deng Q., Weiss N. S. Recency, duration, and progestin content of oral contraceptives in relation to the incidence of endometrial cancer (Washington, USA). Cancer Causes Control. 1994;5(3):227-33. DES. [pmid: 8061170].
de Vries C. S., Bromley S. E., Farmer R. D. Myocardial infarction risk and hormone replacement: differences between products. Maturitas. 2006;53(3):343-50. DES. [pmid: 16040209].
Walker E. M., Rodriguez A. I., Kohn B., Ball R. M., Pegg J., Pocock J. R., Nunez R., Peterson E., Jakary S., Levine R. A. Acupuncture versus venlafaxine for the management of vasomotor symptoms in patients with hormone receptor-positive breast cancer: a randomized controlled trial. J Clin Oncol. 2010;28(4):634-40. NRC. [pmid: 20038728].
Wang C. C., Cheng K. F., Lo W. M., Law C., Li L., Leung P. C., Chung T. K. H., Haines C. J. A randomized, double-blind, multiple-dose escalation study of a Chinese herbal medicine preparation (Dang Gui Buxue Tang) for moderate to severe menopausal symptoms and quality of life in postmenopausal women. Menopause. 2013;20(2):223-231. NOP. [pmid: 22990757].
Warren M. P. A comparative review of the risks and benefits of hormone replacement therapy regimens. Am J Obstet Gynecol. 2004;190(4):1141-67. PTU. [pmid: 15118656].
Wassertheil-Smoller S., Hendrix S. L., Limacher M., Heiss G., Kooperberg C., Baird A., Kotchen T., Curb J. D., Black H., Rossouw J. E., Aragaki A., Safford M., Stein E., Laowattana S., Mysiw W. J. Effect of estrogen plus progestin on stroke in postmenopausal women: the Women's Health Initiative: a randomized trial. JAMA. 2003;289(20):2673-84. DES. [pmid: 12771114].
Watts N. B., Notelovitz M., Timmons M. C., Addison W. A., Wiita B., Downey L. J. Comparison of oral estrogens and estrogens plus androgen on bone mineral density, menopausal symptoms, and lipid-lipoprotein profiles in surgical menopause. Obstet Gynecol. 1995;85(4):529-37. NRC. [pmid: 7898828].
Wehren L. E., Hosking D., Hochberg M. C. Putting evidence-based medicine into clinical practice: comparing anti-resorptive agents for the treatment of osteoporosis. Curr Med Res Opin. 2004;20(4):525-31. PTU. [pmid: 15119990].
Weiderpass E., Adami H. O., Baron J. A., Magnusson C., Bergstrom R., Lindgren A., Correia N., Persson I. Risk of endometrial cancer following estrogen replacement with and without progestins. J Natl Cancer Inst. 1999;91(13):1131-7. DES. [pmid: 10393721].
Weiderpass E., Baron J. A., Adami H. O., Magnusson C., Lindgren A., Bergstrom R., Correia N., Persson I. Low-potency oestrogen and risk of endometrial cancer: a case-control study. Lancet. 1999;353(9167):1824-8. DES. [pmid: 10359406].
Weiner M. G., Barnhart K., Xie D., Tannen R. L. Hormone therapy and coronary heart disease in young women. Menopause. 2008;15(1):86-93. DES. [pmid: 17502840].
Weinstein A. L., Mahoney M. C., Nasca P. C., Hanson R. L., Leske M. C., Varma A. O. Oestrogen replacement therapy and breast cancer risk: a case-control study. Int J Epidemiol. 1993;22(5):781-9. DES. [pmid: 8282455].
Weiss J. M., Saltzman B. S., Doherty J. A., Voigt L. F., Chen C., Beresford S. A., Hill D. A., Weiss N. S. Risk factors for the incidence of endometrial cancer according to the aggressiveness of disease. Am J Epidemiol. 2006;164(1):56-62. DES. [pmid: 16675538].
Weiss L. K., Burkman R. T., Cushing-Haugen K. L., Voigt L. F., Simon M. S., Daling J. R., Norman S. A., Bernstein L., Ursin G., Marchbanks P. A., Strom B. L., Berlin J. A., Weber A. L., Doody D. R., Wingo P. A., McDonald J. A., Malone K. E., Folger S. G., Spirtas R. Hormone replacement therapy regimens and breast cancer risk(1). Obstet Gynecol. 2002;100(6):1148-58. DES. [pmid: 12468157].
Weiss N. S., Farewall V. T., Szekely D. R., English D. R., Kiviat N. Oestrogens and endometrial cancer: effect of other risk factors on the association. Maturitas. 1980;2(3):185-90. DES. [pmid: 7442552].
Wells G., Tugwell P., Shea B., Guyatt G., Peterson J., Zytaruk N., Robinson V., Henry D., O'Connell D., Cranney A. Meta-analyses of therapies for postmenopausal osteoporosis. V. Meta-analysis of the efficacy of hormone replacement therapy in treating and preventing osteoporosis in postmenopausal women. Endocr Rev. 2002;23(4):529-39. PTU. [pmid: 12202468].
Welton A. J., Vickers M. R., Kim J., Ford D., Lawton B. A., MacLennan A. H., Meredith S. K., Martin J., Meade T. W. Health related quality of life after combined hormone replacement therapy: randomised controlled trial. BMJ. 2008;337:a1190. DUP. [pmid: 18719013].
Welty F. K., Lee K. S., Lew N. S., Nasca M., Zhou J. R. The association between soy nut consumption and decreased menopausal symptoms. J Womens Health (Larchmt). 2007;16(3):361-9. NRF. [pmid: 17439381].
Wenger N. Hormone therapy not recommended for chronic disease prevention in menopausal women. Evidence-Based Medicine. 2013;18(3):109-110. NCT. [pmid: 23086385].
Whelan A. M., Jurgens T. M., Trinacty M. Bioidentical progesterone cream for menopause-related vasomotor symptoms: Is it effective?. Annals of Pharmacotherapy. 2013;47(1):112-116. NRD. [pmid: 23249728].
Whelan A. M., Jurgens T. M., Bowles S. K. Natural health products in the prevention and treatment of osteoporosis: systematic review of randomized controlled trials. Ann Pharmacother. 2006;40(5):836-49. NRO. [pmid: 16670364].
White W. B., Grady D., Giudice L. C., Berry S. M., Zborowski J., Snabes M. C. A cardiovascular safety study of LibiGel (testosterone gel) in postmenopausal women with elevated cardiovascular risk and hypoactive sexual desire disorder. Am Heart J. 2012;163(1):27-32. NCT. [pmid: 22172433].
Wiklund I., Holst J., Karlberg J., Mattsson L. A., Samsioe G., Sandin K., Uvebrant M., von Schoultz B. A new methodological approach to the evaluation of quality of life in postmenopausal women. Maturitas. 1992;14(3):211-24. NRC. [pmid: 1508061].
Williamson G., Coppens P., Serra-Majem L., Dew T. Review of the efficacy of green tea, isoflavones and aloe vera supplements based on randomised controlled trials. Food Funct. 2011. NRD.
Williamson-Hughes P. S., Flickinger B. D., Messina M. J., Empie M. W. Isoflavone supplements containing predominantly genistein reduce hot flash symptoms: a critical review of published studies. Menopause. 2006;13(5):831-9. NRD. [pmid: 16932241].
Witt D. M., Lousberg T. R. Controversies surrounding estrogen use in postmenopausal women. Ann Pharmacother. 1997;31(6):745-55. NCT. [pmid: 9184717].
Wolf P. H., Madans J. H., Finucane F. F., Higgins M., Kleinman J. C. Reduction of cardiovascular disease-related mortality among postmenopausal women who use hormones: evidence from a national cohort. Am J Obstet Gynecol. 1991;164(2):489-94. DES. [pmid: 1992690].
Wong V. C., Lim C. E., Luo X., Wong W. S. Current alternative and complementary therapies used in menopause. Gynecol Endocrinol. 2009;25(3):166-74. NRD. [pmid: 19347706].
Woo J., Lau E., Ho S. C., Cheng F., Chan C., Chan A. S., Haines C. J., Chan T. Y., Li M., Sham A. Comparison of Pueraria lobata with hormone replacement therapy in treating the adverse health consequences of menopause. Menopause. 2003;10(4):352-61. NRD. [pmid: 12851519].
Woods N. F., Mitchell E. S., Cray L. A., Ismail R., Taylor-Swanson L., Thomas A. Toward therapeutics for symptom clusters during the menopausal transition and early postmenopause: A systematic review. Menopause. 2012;19(12):1401. NRD.
Wren B. G. The effect of oestrogen on the female cardiovascular system. Med J Aust. 1992;157(3):204-8. PTU. [pmid: 1635499].
Wu A. H., Yu M. C., Tseng C. C., Pike M. C. Body size, hormone therapy and risk of breast cancer in Asian-American women. Int J Cancer. 2007;120(4):844-52. DES. [pmid: 17131315].
Wu F., Ames R., Clearwater J., Evans M. C., Gamble G., Reid I. R. Prospective 10-year study of the determinants of bone density and bone loss in normal postmenopausal women, including the effect of hormone replacement therapy. Clin Endocrinol (Oxf). 2002;56(6):703-11. DES. [pmid: 12072039].
Wu O., Robertson L., Langhorne P., Twaddle S., Lowe G. D., Clark P., Greaves M., Walker I. D., Brenkel I., Regan L., Greer I. A. Oral contraceptives, hormone replacement therapy, thrombophilias and risk of venous thromboembolism: a systematic review. The Thrombosis: Risk and Economic Assessment of Thrombophilia Screening (TREATS) Study. Thromb Haemost. 2005;94(1):17-25. PTU. [pmid: 16113779].
Wuttke W., Seidlova-Wuttke D., Gorkow C. The Cimicifuga preparation BNO 1055 vs. conjugated estrogens in a double-blind placebo-controlled study: effects on menopause symptoms and bone markers. Maturitas. Suppl 1. 2003;44:S67-77. NOP. [pmid: 12609561].
Wuttke W., Raus K., Gorkow C. Efficacy and tolerability of the Black cohosh (Actaea racemosa) ethanolic extract BNO 1055 on climacteric complaints: A double-blind, placebo- and conjugated estrogens-controlled study. Maturitas. 2006;55(SUPPL. 1):S83-S91. NOP.
Wyrwich K. W., Spratt D. I., Gass M., Yu H., Bobula J. D. Identifying meaningful differences in vasomotor symptoms among menopausal women. Menopause. 2008;15(4 Pt 1):698-705. DUP. [pmid: 18369313].
Xia Y., Zhao Y., Ren M., Zhang J., Wang Y., Chang Y., Fu S., Fan G., Zhu Y., Huang Y., Gao X. A randomized double-blind placebo-controlled trial of a Chinese herbal medicine preparation (Jiawei Qing'e Fang) for hot flashes and quality of life in perimenopausal women. Menopause. 2012;19(2):234-44. DUP. [pmid: 22089177].
Xie Q., Chen M. L., Qin Y., Zhang Q. Y., Xu H. X., Zhou Y., Mi M. T., Zhu J. D. Isoflavone consumption and risk of breast cancer: a dose-response meta-analysis of observational studies. Asia Pac J Clin Nutr. 2013;22(1):118-27. NRC. [pmid: 23353619].
Xing S., Wu Y., Liu J., Xu R., Zhang Z., Wang Y. A comparison of two different dosages of conjugated equine estrogen in continuous combined hormone replacement therapy with progestin. Chin Med J (Engl). 2003;116(4):584-7. NRO. [pmid: 12875727].
Xu L. W., Jia M., Salchow R., Kentsch M., Cui X. J., Deng H. Y., Sun Z. J., Kluwe L. Efficacy and side effects of Chinese herbal medicine for menopausal symptoms: A critical review. Evidence-based Complementary and Alternative Medicine 2012. 2012. NRD.
Xu L. W., Jia M., Cui X. J., Deng H. Y., Schroeder S., Salchow R. Chinese herbal medicine for menopausal symptoms. Forum on Immunopathological Diseases and Therapeutics. 2012;3(1):71-89. NRD.
Yaffe K., Vittinghoff E., Ensrud K. E., Johnson K. C., Diem S., Hanes V., Grady D. Effects of ultra-low-dose transdermal estradiol on cognition and health-related quality of life. Arch Neurol. 2006;63(7):945-50. NRQ. [pmid: 16831962].
Yakoot M., Salem A., Omar A. M. Effectiveness of a herbal formula in women with menopausal syndrome. Forsch Komplementmed. 2011;18(5):264-8. NRF. [pmid: 22105039].
Yasui T., Uemura H., Tezuka M., Yamada M., Irahara M., Miura M., Aono T. Biological effects of hormone replacement therapy in relation to serum estradiol levels. Horm Res. 2001;56(1-2):38-44. NOP. [pmid: 11815726].
Ye Y. B., Wang Z. L., Zhuo S. Y., Lu W., Liao H. F., Verbruggen M., Fang S., Mai H. Y., Chen Y. M., Su Y. X. Soy germ isoflavones improve menopausal symptoms but have no effect on blood lipids in early postmenopausal Chinese women: a randomized placebo-controlled trial. Menopause. 2012;19(7):791-8. DUP. [pmid: 22278344].
Ylikorkala O., Rozenberg S. Efficacy and tolerability of fully transdermal hormone replacement in sequential or continuous therapy at two doses of progestogen in postmenopausal women. Maturitas. 2000;37(2):83-93. DUP. [pmid: 11137327].
Yoles I., Yogev Y., Frenkel Y., Hirsch M., Nahum R., Kaplan B. Efficacy and safety of standard versus low-dose Femarelle (DT56a) for the treatment of menopausal symptoms. Clin Exp Obstet Gynecol. 2004;31(2):123-6. NRC. [pmid: 15266766].
Yurcheshen M. E., Guttuso T. Jr., McDermott M., Holloway R. G., Perlis M. Effects of gabapentin on sleep in menopausal women with hot flashes as measured by a Pittsburgh Sleep Quality Index factor scoring model. J Womens Health (Larchmt). 2009;18(9):1355-60. NOP. [pmid: 19708803].
Zaborowska E., Brynhildsen J., Damberg S., Fredriksson M., Lindh-Astrand L., Nedstrand E., Wyon Y., Hammar M. Effects of acupuncture, applied relaxation, estrogens and placebo on hot flushes in postmenopausal women: an analysis of two prospective, parallel, randomized studies. Climacteric. 2007;10(1):38-45. NOP. [pmid: 17364603].
Zang H., Shi H., Speroff L. Low-dose hormone therapy in postmenopausal women in China. Climacteric. 2010;13(6):544-52. NCT. [pmid: 19938946].
Zhou J., Qu F., Nan R., Tang D. The effect of chinese medicinal herbs in relieving menopausal symptoms in ovariectomized chinese women. Explore (NY). 2007;3(5):478-84. NRP. [pmid: 17905357].
Zhu X., Clarke J., Proctor M., Liew Y. L. Chinese herbal medicine for menopausal symptoms. 2011. NCT.
Ziaei S., Moghasemi M., Faghihzadeh S. Comparative effects of conventional hormone replacement therapy and tibolone on climacteric symptoms and sexual dysfunction in postmenopausal women. Climacteric. 2010;13(2):147-56. NRC. [pmid: 19731119].
Zweifel J. E., O'Brien W. H. A meta-analysis of the effect of hormone replacement therapy upon depressed mood. Psychoneuroendocrinology. 1997;22(3):189-212. NRD. [pmid: 9203229].