# Literature Search Strategies

Last search date: 1/17/2014

## Search Strategy: PubMed

1. "Menopause"[Mesh] OR menopause OR menopausal OR "post-menopause" OR postmenopause OR "post-menopausal" OR postmenopausal OR climacteri* OR perimenopause OR "peri-menopause" OR "peri-menopausal" OR perimenopausal
2. "therapy" [Subheading] OR "Therapeutics"[Mesh] OR "Estrogen Replacement Therapy"[Mesh] OR "Drug Therapy"[Mesh] OR "drug therapy" [Subheading] OR "therapeutic use" [Subheading] OR "Hormone Replacement Therapy"[Mesh] OR "Complementary Therapies"[Mesh] OR "Estrogens"[Mesh] OR "Progestins"[Mesh] OR estrogen* OR progestin* OR "hormone replacement" OR antidepressant* OR eszopiclone OR clonidine OR methyldopa OR bellergal OR gabapentin OR pregabalin OR isoflavone* OR "red clover" OR "black cohosh" OR cimicifuga OR "st. johns wort" OR ginseng OR flaxseed OR "vitamin E" OR "dong quai" OR "Dehydroepiandrosterone"[Mesh] OR "Androgens"[Mesh] OR DHEA OR dehydroepiandrosterone OR "androgenic agents" OR "androgenic compounds" OR androgen*
3. Subset: Systematic Review OR Publication Type: Meta-analysis OR (“meta-analysis” OR metaanalysis OR “systematic review”)
4. Limits: English, Human
  Added - (1 AND 2) AND (“meta-analysis” OR metaanalysis OR “systematic review”) NOT in previous set and in English and relevant = 31 additional nonindexed records

### Vasomotor symptoms

("Hyperhidrosis"[Mesh]) OR "Hot Flashes"[Mesh] OR "vasomotor symptoms" OR "hot flashes" OR "night sweats" OR sweats OR flushes - + (1 AND 2) AND RCT(pt)/Eng/Human

### Sleep disturbance

("Dyssomnias"[Mesh]) OR "Sleep Initiation and Maintenance Disorders"[Mesh] OR insomnia OR sleeplessness OR "early awakening" OR "somatic complaints" - +(1 AND 2) AND RCT(pt)/Eng/Human

### Psychological symptoms

("Behavioral Symptoms"[Mesh]) OR "Mood Disorders"[Mesh] OR irritability OR depression OR despair OR anxiety OR “difficulty concentrating” OR “over-reacting” OR forgetfulness OR “reminiscence lapses” OR “mood swings” OR “temper swings” OR “emotional flare-ups” OR weepiness - +(1 AND 2) AND RCT(pt)/Eng/Human

### Urogenital atrophy

"Female Urogenital Diseases"[Mesh] OR "Urogenital System/pathology"[Mesh] OR "urogenital disorders" OR ((vulva* OR vagina* OR vulvovaginal OR urinary OR genital OR urogenital) AND atrophy) OR "atrophic vaginitis" +(1 AND 2) AND RCT(pt)/Eng/Human

### Sexual function

"Sexual Dysfunction, Physiological"[Mesh] OR "Sexual Dysfunctions, Psychological"[Mesh] OR "Libido"[Mesh] OR "female sexual dysfunction" OR "female sexual dysfunctions" OR "hypoactive sexual desire disorder" OR "sexual function" OR "sexual desire" OR "sexual satisfaction" +(1 AND 2) AND RCT(pt)/Eng/Human

### Quality of Life

"Quality of Life"[Mesh] OR "quality of life" OR "well-being" +(1 AND 2) AND RCT(pt)/Eng/Human

### Harms Search

1. "Menopause"[Mesh] OR menopause OR menopausal OR "post-menopause" OR postmenopause OR "post-menopausal" OR postmenopausal OR climacteri* OR perimenopause OR "peri-menopause" OR "peri-menopausal" OR perimenopausal
2. (((("adverse effects" [Subheading]) OR "complications" [Subheading]) OR ( "poisoning" [Subheading] OR "Poisoning"[Mesh] )) OR "drug effects" [Subheading]) OR "Drug Toxicity"[Mesh]
3. "Estrogen Replacement Therapy"[Mesh] OR "Hormone Replacement Therapy"[Mesh] OR "Estrogens"[Mesh] OR "Progestins"[Mesh] OR estrogen* OR progestin* OR "hormone replacement" OR antidepressant* OR eszopiclone OR clonidine OR methyldopa OR bellergal OR gabapentin OR pregabalin OR isoflavone* OR "red clover" OR "black cohosh" OR cimicifuga OR "st. johns wort" OR ginseng OR flaxseed OR "vitamin E" OR "dong quai" OR ("Dehydroepiandrosterone"[Mesh]) OR "Androgens"[Mesh] OR DHEA OR dehydroepiandrosterone OR "androgenic agents" OR "androgenic compounds" OR androgen*)
4. Subset: Systematic Review OR Publication Type: Randomized controlled trial OR ("placebo-controlled" OR (placebo AND (control OR controlled))) OR (observational OR cohort OR "case-control" OR "cross-sectional")
5. Limits: English, Human
  (((1 AND 2) AND 3) AND 4)/English/Human

## EMBASE

1. 'menopause'/exp OR menopausal OR 'post-menopause'/exp OR 'postmenopause'/exp OR 'post-menopausal' OR postmenopausal OR climacteri* OR 'perimenopause'/exp OR 'peri-menopause' OR 'peri-menopausal' OR perimenopausal AND [humans]/lim AND [english]/lim AND [embase]/lim =60511
2. 'estrogen replacement therapy'/exp OR 'drug therapy'/exp OR 'hormone replacement therapy'/exp OR estrogen* OR progestin* OR 'hormone replacement'/exp OR antidepressant* OR 'eszopiclone'/exp OR 'clonidine'/exp OR 'methyldopa'/exp OR 'bellergal'/exp OR 'gabapentin'/exp OR 'pregabalin'/exp OR isoflavone* OR 'red clover'/exp OR 'black cohosh'/exp OR 'cimicifuga'/exp OR 'st johns wort'/exp OR 'ginseng'/exp OR 'flaxseed'/exp OR 'vitamin e'/exp OR 'dong quai'/exp OR [underlined: (DHEA OR dehydroepiandrosterone OR "androgenic agents" OR "androgenic compounds" OR androgen*)]
  (1 AND 2) AND [humans]/lim AND [english]/lim AND [embase]/lim

Cochrane searches were also performed for menopause/post-menopausal/climacteric to detect new references since the main search.