# Abbreviations

Acronym: Definition
AHRQ: Agency for Healthcare Research and Quality
BMI: body mass index
CAM: complementary and alternative medicine
CE: conjugated estrogen
CEE: conjugated equine estrogen
CER: comparative effectiveness review
CES-D: Center for Epidemiologic Studies Depression Scale
CHD: coronary heart disease
CI: confidence interval
CV: Cardiovascular
DHEA: Dehydroepiandrosterone
EPC: evidence-based practice center
E2V: estradiol valerate
FDA: Food and Drug Administration
GCS: Greene Climacteric Scale
GRADE: Grading of Recommendations Assessment, Development, and Evaluation
HF: hot flushes
HFNS: hot flushes and night sweats
HOPE: Health Outcomes Prevention Evaluation trial
HOPE-TOO: Health Outcomes Prevention Evaluation- The Ongoing Outcomes trial
HR: hazards ratio
HRT: hormone replacement therapy
IMS: International Menopause Society
IU: international unit
KI: Kupperman Index
MARIE: Mamma carcinoma Risk factor Investigation
MENQOL: Menopause-specific Quality of Life
MI: myocardial infarction
MPA: medroxyprogesterone acetate
MRS: Menopause Rating Scale
MSHF: moderate-to-severe hot flushes
MSHFNS: moderate-to-severe hot flushes and night sweats
MSVS: moderate-to-severe vasomotor symptoms
N: number
NAMS: North American Menopause Society
NETA: norethindrone acetate
NPNH: nonprescription nonhormone
NR: not reported
PICOTS: Population(s), Interventions, Comparators, Outcomes, Timing, and Setting
PMS: premenstrual syndrome
PND: postnatal depression
QOL: quality of life
RCT: randomized controlled trial
RR: relative risk
SD: standard deviation
SNRI: serotonin-norepinephrine reuptake inhibitor
SRC: Scientific Resource Center
SSRI: selective serotonin reuptake inhibitor
STRAW: Stages of Reproductive Aging Workshop
TEP: Technical Expert Panel
THF: total hot flushes
THFNS: total hot flushes and night sweats
TOO: task order officer
USPSTF: United States Preventive Services Task Force
VAS: Visual Analog Scale
WHI: Women’s Health Initiative
WHQ: Women’s Health Questionnaire
WHS: Women’s Health Study
WISDOM: Women’s International Study of Long Duration Oestrogen after Menopause