# Results

## Introduction

In this chapter, we describe the results of the literature searches, and then present the results of each Key Question (KQ). We were unable to identify any studies that addressed KQ 3 (provider characteristics).

A list of acronyms and abbreviations used in this report is available following the list of references, along with a glossary of selected terms. The Appendices include Appendix A, Literature Search Methods; Appendix B, Full-length Review of Excluded Studies; Appendix C, Risk of Bias Assessments; Appendix D, Study Selection Criteria and Description of Treatment; Appendix E, Baseline Demographic and Tumor Characteristics; Appendix F. Evidence Tables; and Appendix G, Ongoing Clinical Trials.

Studies that addressed KQ 1 reported data for patient-oriented outcome measures such as overall survival, all-cause mortality, prostate cancer–specific mortality, quality of life, and adverse events. None of the studies that addressed either KQ 2 or KQ 4 reported on adverse events based on patient subgroups (i.e., patient characteristics or tumor characteristics). All the studies that addressed either KQs 2 or 4 reported data only for outcome measures such as overall survival, all-cause mortality, or prostate cancer–specific mortality. We did not identify any publications of interest that addressed KQ 3 (studies with information on provider or hospital characteristics that evaluated efficacy of the different treatment options in men with clinically localized prostate cancer).

## Results of Literature Searches

Our searches of the literature identified 5,210 potentially relevant articles. We excluded 1,508 articles by reviewing the titles, 3,420 by reviewing the abstracts, and 221 by reviewing the full-length articles. Figure 2 is a flow chart that describes in detail the exclusion process and the reasons for the exclusion at each review level.

Figure 2 Literature flow diagram

This figure summarizes the literature review workflow identifying current evidence related to clinically localized prostate cancer. Our search of peer-reviewed journals and gray literature identified 5,210 records potentially relevant to the topic. We excluded 1,508 articles based on title screening alone. Of the remaining 3,702 abstracts, we excluded 3,420 after full abstract review. Most of the articles were excluded because they were not relevant to the key questions, they were not clinical studies or were not an acceptable study design. We retrieved 282 full-length articles for review, of which 221 were excluded for various reasons. The most common reason for exclusion at this level was a nonrandomized comparative study design with no attempt to control for selection bias or with fewer than 500 patients. We included 61 articles describing 52 unique studies for data extraction and analysis. Of these included studies, 52 addressed KQ 1, 13 addressed KQ 2, none addressed KQ 3, and 20 addressed KQ 4.

The remaining 61 publications describing 52 unique studies made up the evidence base for this review. All 52 studies met the inclusion criteria for review for KQ 1. Thirteen of these studies also met the inclusion criteria for KQ 2, and 20 of them further met the inclusion criteria for KQ 4. Appendix B lists studies excluded after full-length review.

## Key Question 1 Comparative Risks and Benefits of Therapies for Clinically Localized Prostate Cancer

### Key Points

- Progression to metastases was reduced at 12 years among patients undergoing radical prostatectomy (RP) compared to those receiving watchful waiting (WW; based on two medium risk-of-bias randomized trials).15,25,33,34 (Strength of evidence: moderate.)
- Urinary incontinence (as an indirect measure of quality of life [QOL]) was lower among patients receiving WW compared with those undergoing RP (based on 1 medium and 1 high risk-of-bias randomized trial).15,25,33,34 (Strength of evidence: low.)
- Overall survival was higher in patients treated with three-dimensional conformal radiotherapy (3D-CRT) plus androgen-deprivation therapy (ADT) than in patients treated with 3D-CRT alone (based on a single low risk-of-bias randomized study).35 (Strength of evidence: low.)
- All-cause mortality was lower in patients treated with 3D-CRT plus ADT compared with patients treated with 3D-CRT alone (based on a single low risk-of-bias randomized study).35 (Strength of evidence: low.)
- Prostate cancer–specific mortality was lower in patients treated with 3D-CRT plus ADT than in patients treated with 3D-CRT alone (based on a single low risk-of-bias randomized study).35 (Strength of evidence: low.)
- For other outcomes/comparisons, strength of evidence from the randomized studies is insufficient to draw any conclusion.
- All-cause mortality was significantly lower in patients treated with RP than in patients treated with external beam radiation therapy (EBRT);36-40, 42 based on consistent evidence from 6 nonrandomized comparison studies with high risk of bias). (Strength of evidence: low.)
- Prostate cancer–specific mortality was significantly lower in patients treated with RP than in patients treated with EBRT37-42 (based on consistent evidence from 6 nonrandomized comparison studies with high risk of bias). (Strength of evidence: low.)

### Detailed Synthesis

The main treatment options for clinically localized prostate cancer are identified and summarized in Table 5. In this section, we summarize findings from randomized controlled trials (RCTs) and describe additional data from the nonrandomized comparative studies.

#### Randomized Controlled Trials

##### Study Characteristics

General information, including detailed baseline demographic and tumor characteristics about the 8 RCTs in 16 unique publications included for this KQ, appears in Table E-1 of Appendix E. The eight RCTs included 4,375 men at enrollment (1,131 underwent RP, 1,114 received EBRT alone, 987 received EBRT plus ADT, 715 were managed by observation or WW, 122 received cryotherapy, 104 received CRT alone, 102 received CRT plus ADT, and 100 received BT). The RCTs enrolled between 120 and 1,979 patients each.

Five studies reported the mean age of patients by treatment group. The mean age ranged from 60.0 to 68.4 years; three studies reported median patient age that ranged from 68.6 to 74.0 years. Five studies did not report the race or ethnicity of enrolled patients. For the three studies reporting this characteristic the percentage of white patients ranged from 60% to 100%.25,43,44 Four studies did not report the comorbidity status of enrolled patients. One study each reported comorbidity as American Society of Anesthesiology Scores,45 percentage with a variety of cardiovascular diseases,25 percentage with any comorbitity,43 and Adult Comorbidity Evaluation Scores.35

All eight trials reported prostate-specific antigen (PSA) levels and Gleason scores of enrolled patients and included at least 85% with clinical T stage T3a or lower as required for inclusion in this comparative effectiveness review. The population for seven studies was patients with T1 and T2 prostate cancer.15,25,35,43-46 One study47 included patients with T2a, T2b, T2c, T3a, and T3b,c prostate cancer. Other tumor characteristics were reported inconsistently, including prostate volume, risk category, differentiation, World Health Organization grade, presence of positive margins, and percentage with extracapsular extension at histology. Five studies35,44-47 reported patient exclusion criteria, four of which excluded patients with a history of radiation exposure.35,44,45,47

Two studies were conducted in the United States,25,35 three in Italy,44-46 one in Canada47; and the remaining two studies were international.33,43 Three were multicenter RCTs25,33,43 and five35,44-47 were single-center RCTs.

One of the included RCTs provided details of expertise of the participating surgeon. The surgeon had performed more than 600 laparoscopic radical prostatectomies (LRPs) and 100 robot-assisted radical prostatectomies before completing the RCT comparing these two surgical techniques.45 One study33 reported that radical excision of the tumor was given priority over nerve-sparing, one study25 reported that the surgical technique was at the discretion of the surgeon, and two studies44,46 reported that a bilateral nerve-sparing technique was performed on all patients by a single surgeon.

Radiation therapy also varied among the included studies. In one study,43 radiotherapy was administered in daily 1.8 Gray (Gy) fractions, with 46.8 Gy delivered to the prostate and regional lymph nodes, followed by 19.8 Gy to the prostate. Another study reported a prescribed radiation dose of Gy was increased to 70 Gy in early 2000 and finally to 73.5 Gy in late 2002 in response to changing standards of practice.47 One study44 administered brachytherapy (BT) using a transperineal template-guided peripheral loading real-time technique and seeds of iodine 125.

ADT also varied among included studies. One study43 reported flutamide (250 mg) was administered, and another study35 did not report the specific dose of the flutamide. Patient enrollment criteria and description of treatment details appear in Table D-1 of Appendix D.

The treatment comparisons assessed in the eight RCTs included RP with observation or WW (2 studies),25,33 two different forms of RP (2 studies),45,46 RP with BT,44 3D-CRT versus 3D-CRT plus ADT,35 EBRT versus EBRT plus ADT,35,43 and EBRT versus cryotherapy.47Three studies reported all-cause mortality,25,33,35 five studies reported prostate cancer–specific mortality,15,25,35,43,47 three studies reported overall survival,35,43,47 five studies in six publications measured QOL,15,43-45,47,48 six studies reported adverse events,15,25,43,45-47 three studies reported distant metastases,15,25,43 five studies reported on biochemical failure,35,43,44,47,49 and two studies reported biochemical disease–free survival.45,50

See Table 12 and Table 13 for a summary of the patient characteristics, treatments assessed, outcomes reported, and duration of followup.

Table 12 Overview of randomized controlled trials across primary treatment categories (4 trials): Key Question 1

Study | Interventions and Number of Patients | Subjects | Outcomes | Duration
Wilt et al. 2012^25^, Wilt et al. 2009^24^ Prostate Intervention vs. Observation Trial (PIVOT) | RP (364 patients) vs. observation (367 patients) | Age 75 years or younger, T1–T2NxM0, PSA levels <50 ng/mL | All-cause mortality PCSM Distant metastases Adverse events | Median followup of 10 years
Bill-Axelson et al. 2013^48^, Bill-Axelson et al. 2011^33^, Johansson et al. 2011;^51^ Holmberg et al. 2012;^34^ and Bill-Axelson et al. 2008^15^ Scandinavian Prostate Cancer Group-4 (SPCG-4) trial | RP (347 patients) vs. watchful waiting (348 patients) | Age 77 years or younger, T1b, T1c, T2, PSA levels <50 ng/mL | Overall mortality PCSM Distant metastases Adverse events QOL | Median followup of 15 years
Giberti et al. 2009^44^ | RRP (100 patients) vs. brachytherapy using iodine 125 (100 patients) | Caucasian men, T1c or T2a, PSA value ≤10 ng/mL and Gleason sum ≤6) | Biochemical disease-free survival QOL Adverse events | Followup of 5 years
Donnelly et al. 2010^47^ Same study as Robinson et al. 2009^52^ | EBRT (122 patients) vs. cryotherapy (122 patients) | Median age 68.6 years (EBRT) and 69.4 years (cryotherapy), T2a, T2b, T2c, T3a, T3b,c prostate adenocarcinoma, PSA levels ≤20 ng/mL | Overall survival PCSM Biochemical failure QOL Adverse events | 3years, 5 years, and 7 years

Note: See Tables 1–3 for definitions of T, N, M cancer stages.

Abbreviations: EBRT=external beam radiation therapy; PCSM=prostate cancer–specific mortality; PSA=prostate-specific antigen; QOL=quality of life; RP=radical prostatectomy; RRP=radical retropubic prostatectom.

Table 13 Overview of randomized controlled trials within primary treatment categories (4 trials): Key Question 1

Study | Interventions and Number of Patients | Subjects | Outcomes | Duration
Porpiglia et al. 2012^45^ | RARP: 60 patients vs. LRP: 60 patients | Age 40–75 years, PCa T1 through T2N0M0 clinically staged according to TNM 2009 | Biochemical recurrence–free survival QOL Adverse events | Followup of 1 year
Jones et al. 2011^43^ | EBRT (992 patients) vs. EBRT plus short-term ADT (987 patients) | Age 71 years or younger, T1b, T1c, T2a, T2b prostate adenocarcinoma, PSA levels ≤20 ng/mL | Overall survival PCSM Biochemical failure Distant metastases QOL Adverse events | Median followup of 9.1 years
D'Amico et al. 2008^35^, Nguyen et al. 2010^53^ | 3D-CRT (104 patients) vs. 3D-CRT plus ADT (102 patients) | Age <70, 70–75, and >75 years, PSA ≤4 up to ≥20, Gleason score ≤6 to 10, T1b–T2b patients (T1, T2 patients who had at least a 10-year life expectancy excluding death from prostate cancer) | Overall survival All-cause mortality PCSM | Median followup of 7.6 years
D'Amico et al. 2008^49^ Study is a subgroup analysis of the 2008 D'Amico study35 and Nguyen et al. 2010^53^ | 3D-CRT (104 patients) vs. 3D-CRT plus 6 months of both LHRH and antiandrogen vs. 3D-CRT (73 patients) plus 6 months of both LHRH and less than 6 months of antiandrogen (29 patients) | Age <70, 70–75, and >75 years, PSA ≤4 up to [underlined: ≥]20, Gleason score ≤6 to 10, T1b–T2b patients (T1, T2 patients who had at least a 10-year life expectancy excluding death from prostate cancer) | Biochemical failure | Median followup 8.2 years
Martis et al. 2007^46^ | Radical retropubic prostatectomy (100 patients) vs. radical perineal prostatectomy (100 patients) | T1, T2 | Adverse events | Followup of 2 years

Abbreviations: ADT=Androgen-deprivation therapy; EBRT=external beam radiation therapy; 3D-CRT=three-dimensional conformal radiation therapy; LRP=laparoscopic radical prostatectomy; LHRH=luteinizing hormone-releasing hormone; PCSM=prostate cancer–specific mortality; PSA=prostate-specific antigen; QOL=quality of life; RARP=robot-assisted radical prostatectomy.

##### Risk of Bias

Our risk-of-bias (ROB) assessments for the eight studies appear in Table C-1 of Appendix C. Seven of the eight RCTs were categorized as medium ROB for all outcomes excluding the QOL outcome. Only D'Amico et al. received a rating of low ROB.35 Common reasons for assigning a medium rating to the studies were lack of concealment of allocation, failure to use an intent-to-treat analysis, and/or less than 85% of patients had available data at the timepoint of interest. All eight RCTs also reported QOL. Five studies reporting QOL received a rating of high ROB because in addition to the limitations noted above, the study did not blind or failed to report the blinding status of outcome assessors for this subjective outcome.33,43,45-47 Gilberti et al. and Wilt et al. each received a rating of medium ROB for the QOL outcome because they were blinded RCTs but with an additional flaw such as less than 85% of patients had available data at the timepoint of interest (Wilt) or intention-to-treat analysis was not reported (Gilberti).25,44 D'Amico et al. received a low-ROB rating for the QOL outcome.35

##### Findings

All abstracted data for the outcome measures reported by RCTs that address this KQ appear in Table F-1 (all-cause mortality), Table F-3 (overall survival), Table F-5 (prostate cancer–specific mortality), Table F-7 (biochemical failure), Table F-9 (biochemical progression–free survival), Table F-11 (progression to metastasis), Table F-13 (QOL), and Table F-15 (reported adverse events) of Appendix F. Table 14 summarizes major findings reported by the RCTs and is intended to provide a roadmap to the abstracted data, including the key statistics, for each comparison and reported outcome.

Table 14 Major findings reported by randomized controlled trials for Key Question 1

Treatments Being Compared | Outcome | Evidence Base | Major Findings Reported in the Study | Detailed Results Abstracted
RP vs. WW | All-Cause Mortality | SPCG-4 Bill-Axelson et al.15,33,34 | SPCG-4: All-cause mortality was lower among men who were treated with RP than those in WW at the 15-year followup. The SPCG-4 reported a statistically significant reduction for all-cause mortality among men who underwent RP (RR 0.75; 95% CI, 0.61 to 0.92) and a 6.6% ARR (95% CI, -1.3 to 14.5; 47.8% deaths in the RP vs. 57.8% deaths in WW) after 15-year followup. At 12-year followup, the all-cause specific mortality was RR 0.84, 95% CI, 0.65 to 1.03 and a 4.6% ARR (-1.1 to 10.5; 39.5% deaths in the RP vs. 44.8% deaths in WW). | Table F-1 of Appendix F
RP vs. WW | All-Cause Mortality | PIVOT Wilt et al.25 | PIVOT: No significant reduction in all-cause mortality among men who were treated with RP compared with WW after 12-year followup (HR 0.88; 95% CI, 0.71 to 1.08) and an ARR of 2.9 % (95% CI, -4.1% to 10.3; 47% deaths in RP vs.49.9% deaths in WW). | Table F-1 of Appendix F
RP vs. WW | PCSM | SPCG-4 Bill-Axelson et al.15,33,34 | SPCG-4: PCSM was lower among men who were treated with RP than those in WW at 12- and 15-year followup periods in the WW group. The SPCG-4 reported a statistically significant reduction for PCSM among men who underwent RP (RR 0.62; 95% CI, 0.44 to 0.87) and a 6.1% ARR (95% CI, 0.2% to 12.0%; 14.6% deaths in RP vs. 20.7% deaths in WW) after 15-year followup. At 12-year followup, the PCSM was also reduced among men who underwent RP compared with WW (RR 0.65; 95% CI, 0.45 to 0.94). The ARR was 5.4% (95% CI -0.2% to 11.1%) with 12.5% deaths in RP vs. 17.9% deaths in WW. | Table F-5 of Appendix F
RP vs. WW | PCSM | PIVOT Wilt et al.25 | PIVOT: No significant reduction in PCSM among men who were treated with RP compared with WW after 12-year followup (HR 0.63; 95% CI, 0.36 to 1.09) and an ARR of 3.0% (95% CI, -1.1 to 6.5; 4.4% deaths in RP vs. 7.4% deaths in WW). | Table F-5 of Appendix F
RP vs. WW | Progression to metastases | SPCG-4 Bill-Axelson et al.15,33,34 | SPCG-4: The percentage of patients with bone metastases at median followup 12 years (RR 0.65; 95% 0.47 to 0.88) or 15 years (RR 0.59; 95% CI, 0.45 to 0.79) was lower for the RP group than the WW group | Table F-11 of Appendix F
RP vs. WW | Progression to metastases | PIVOT Wilt et al.25 | PIVOT: The percentage of patients with bone metastases at median followup 10 years was lower for the RP group than the WW group (HR 0.40; 95% 0.22 to 0.70) | Table F-11 of Appendix F
RP vs. WW | QOL | SPCG-4 Johansson et al.51 Bill-Axelson et al.48 | SPCG-4: At a median followup of 12.2 years (range 7–17 years), no significant differences exist in patient-reported anxiety, depressed mood, well-being, QOL, and sense of meaningfulness between the RP and WW groups. At 8-year followup, men who underwent RP regularly reported more urinary leakage; impaired erection, intercourse, and libido; and fewer obstructive voiding symptoms. At the 4-year followup, the prevalence of urinary leakage was greater after RP than with WW, while erectile function did not differ between groups. Common adverse events in 1 year after RP included urinary leakage and impotence. | Table F-13 in Appendix F
RP vs. WW | QOL | PIVOT Wilt et al.25 | PIVOT: At 2-year followup, more men in the RP group than in the WW group reported erectile dysfunction and urinary incontinence. Patient-reported bowel dysfunction, however, was comparable in both groups. | Table F-13 in Appendix F
RP vs. WW | Adverse events | PIVOT Wilt et al.25 | Reported adverse events within 30 days after RP included 1 death, wound infection (4.3%), surgical repair, urinary tract infection, and bleeding requiring blood transfusion. | Table F-15 in Appendix F
RARP vs. LRP | Biochemical recurrence–free survival | Porpiglia et al.45 | The authors report that there was no difference in PSA values between the 2 groups at any visit through the 1-year followup. PSA values were not reported in the publication. BRFS rates were 98% in the RARP group and 92.5% in the LRP, a non-significant difference. | Table F-7 in Appendix F
RARP vs. LRP | QOL | Porpiglia et al.45 | Continence rates were significantly higher in the RARP through 1 year of followup, 95% and 83.3%, respectively. Among potent patients undergoing nerve-sparing techniques, 80% of RARP patients and 54.2% of LRP patients experienced a recovery of erections at the 1-year followup. | Table F-13 in Appendix F
RARP vs. LRP | Adverse events | Porpiglia et al.45 | This study reported Clavien medical and surgical adverse events in the early (30 days) and intermediate (31–90 day) period and graded them as minor or major. No statistical analysis or conclusions could be drawn given how the data were reported. | Table F-15 in Appendix F
RPP vs. RRP | QOL | Martis et al.46 | At 6 and 24 months, no significant between-group difference for urinary continence; significantly more patients in the RRP group had erectile function at 24 months. | Table F-13 in Appendix F
RRP vs. BT | Biochemical disease–free survival | Giberti et al.44 | At 5-year followup, the rates of biochemical disease–free survival were comparable for the RRP and BT groups. | Table F-7 in Appendix F
RRP vs. BT | QOL | Giberti et al.44 | A deterioration of physical and emotional functions occurred in both groups at the 1-year followup period. No differences between the groups were found in either the physical or emotional functions after 5-year followup. At 6-month followup, commonly reported events include urinary incontinence for the RRP group and urinary irritation and proctitis for the BT group. Both groups reported falling erectile function at 6-month followup. No difference was found in erectile function and urinary disorders at the 5-year followup period in either study group. | Table F-13 in Appendix F
3D-CRT vs. 3D-CRT plus ADT | Overall survival | D'Amico et al.35 Same study as Nguyen et al.53 | The study reported that overall survival was higher for men in the 3D-CRT plus ADT group than in men receiving 3D-CRT alone. The Kaplan-Meier 8-year survival estimate was 74% in the 3D-CRT plus ADT group compared with 61% in the 3D-CRT-alone group. | Table F-3 in Appendix F
3D-CRT vs. 3D-CRT Plus ADT | PCSM | D'Amico et al.35 Same study as Nguyen et al.53 | The study reported that PCSM at a median followup of 7.6 years favored 3D-CRT plus ADT over 3D-CRT monotherapy: HR: 4.1 (1.4 to 12.1), p=0.01. | Table F-5 of Appendix F
3D-CRT vs. 3D-CRT plus 6 months of both LHRH agonist and antiandrogen flutamide vs.3D-CRT plus 6 months of both LHRH agonist and less than 6 months of antiandrogen flutamide | Biochemical failure | D'Amico et al.49 Subgroup analysis of 35,53 | After a median followup of 8.2 years, estimates of PSA recurrence were significantly lower in men who received 6 months of antiandrogen flutamide compared with those who received no ADT. After a median followup of 8.2 years, there was no significant difference in the PSA recurrence between men who received antiandrogen flutamide for 6 months compared with those who received less than 6 months of antiandrogen flutamide. After a median followup of 8.2 years, there was no significant difference in the PSA recurrence between men who received less than 6 months of antiandrogen flutamide compared with those who received no ADT. | Table F-7 of Appendix F
EBRT vs. EBRT plus ADT | Overall survival | Jones et al.43 | Overall survival was higher for men in the EBRT plus ADT group than in men receiving EBRT alone. The 10-year overall survival was increased to 62% in the EBRT plus short-term ADT group compared with 57% in the EBRT alone group. | Table F-3 in Appendix F
EBRT vs. EBRT plus ADT | PCSM | Jones et al.43 | Authors reported a reduction in the PCSM among the men who received EBRT plus ADT compared with EBRT alone. | Table F-5 of Appendix F
EBRT vs. EBRT plus ADT | Biochemical failure | Jones et al.43 | The 10-year rate of biochemical failure was reduced to 26% in the EBRT plus ADT group from 41% in the EBRT alone group. | Table F-7 of Appendix F
EBRT vs. EBRT plus ADT | Progression to metastases | Jones et al.43 | The 10-year cumulative incidence of distant metastases was reduced to 6% in the EBRT plus ADT group from 8% in the EBRT alone group. | Table F-11 of Appendix F
EBRT vs. EBRT plus ADT | QOL | Jones et al.43 | At 1 year, 31% of the patients in the EBRT alone group compared with 21% in the EBRT plus ADT group reported always/almost always (effect of short-term ADT on erectile function) on the Sexual Adjustment Questionnaire. | Table F-13 in Appendix F
EBRT vs. EBRT plus ADT | Adverse events | Jones et al.43 | The men in the EBRT alone group had an increased incidence of grade 3 or higher acute and late gastrointestinal toxicity occurring up to 90 days after the start of EBRT. | Table F-15 in Appendix F
EBRT vs. cryotherapy | Overall survival | Donnelly et al.47 | There was no difference in overall survival at 5 years between both groups (EBRT 88.5% vs. cryotherapy 89.7%; difference 1.2 (-6.8–9.2). | Table F-3 in Appendix F
EBRT vs. cryotherapy | PCSM | Donnelly et al.47 | There was no difference in PCSM at 5 years between both groups (96.1% vs. 96.4%; Difference 0.3 (-4.8–5.4). | Table F-5 of Appendix F
EBRT vs. cryotherapy | Biochemical failure | Donnelly et al.47 | Biochemical failure at 3 years (% reaching end point): 23.7% (EBRT) vs. 23.9% (cryotherapy); Difference 0.2 (-10.8 – 11.2). Biochemical failure at 5 years (% reaching end point): 37.7% (EBRT) vs. 31% (cryotherapy); Difference -6.7 (-19.4 – 6.0) Biochemical failure at 7 years (% reaching end point): 43.9% (EBRT) vs. 33.2% (cryotherapy); Difference -0.7 (-24.4 – 2.9). | Table F-7 of Appendix F
EBRT vs. cryotherapy | QOL | Robinson et al.52 Same study as Donnelly et al.47 | At 3 years, men in the EBRT group experienced slightly lower urinary function scores compared with cryotherapy (88.6 vs. 93.0, p=0.049). At 3 years, there was no difference in bowel function scores between men in the EBRT and cryotherapy group (84.1 vs. 88.1, p=0.092). At 3 years, men in the cryotherapy group experienced lower sexual function scores compared with EBRT (16.0 vs. 36.7, p<0.001). | Table F-13 in Appendix F
EBRT vs. cryotherapy | Adverse events | Donnelly et al.47 | 14 patients suffered 16 grade 3 adverse events in the EBRT group. 12 patients suffered 13 grade 3 adverse events in the cryotherapy group. | Table F-15 in Appendix F

Abbreviations: ADT=Androgen-deprivation therapy; ARR=absolute risk reduction; BT=brachytherapy; EBRT=external beam radiation therapy; CI=confidence interval; 3D-CRT=three-dimensional conformal radiation therapy; HR=hazard ratio; LHRH=luteinizing hormone-releasing hormone; LRP=laparoscopic radical prostatectomy; PCSM=prostate cancer–specific mortality; PIVOT=Prostate Cancer Intervention Versus Observation Trial; PSA=prostate-specific antigen; QOL=quality of life; RARP=robot-assisted radical prostatectomy; RP=radical prostatectomy; RPP=radical perineal prostatectomy; RRP=radical retropubic prostatectomy; RR=relative risk; SPCG-4=Scandinavian Prostate Cancer Group-4 study; WW=watchful waiting.

#### Nonrandomized Comparative Studies

##### Study Characteristics

General information, including baseline demographic and tumor characteristics of the 44 nonrandomized comparative studies in 45 unique publications (of 500 or more patients) that addressed this KQ, appears in Table E-2 of Appendix E. Enrollment ranged from 614 to 275,200 patients. Eleven of the included studies drew their sample from the National Cancer Institute's Surveillance Epidemiology and End Results (SEER) database.

Of the men enrolled and treated with surgery, 164,432 underwent RP, 15,686 received RP plus radiation, 7,537 received radical retropubic prostatectomy (RRP), 5,852 received robotic-assisted laparoscopic radical prostatectomy (RALRP), and 2,208 LRP.

Among the nonsurgical patients enrolled, 1,959 received radiation, 164,203 EBRT monotherapy, 64,116 received BT monotherapy, 24,168 received combination therapy with BT plus EBRT, 924 received combination therapy with BT plus intensity-modulated radiation therapy (IMRT), 13,295 received IMRT monotherapy, 13,815 received 3D-CRT monotherapy, 2,264 received 3D-CRT plus IMRT, 1,039 were treated with external beam image-guided radiation therapy (EB-IGRT), 734 were treated with image-guided radiation therapy (IGRT), 10,820 received ADT monotherapy, 1,024 received cryotherapy monotherapy, 6,775 received BT plus hormone therapy combination therapy, 53,322 were managed by observation, 324 were managed by WW, 685 proton therapy, 260 received high-intensity focused ultrasound (HIFU) monotherapy, and 270 received HIFU plus ADT combination therapy.

Patient followup across the studies ranged from 1.09 years54 to 15 years.38,55 Patients ranged in age from 58^56^ to 85 years.57-60 Forty of the 44 studies were conducted in the United States, and one each was conducted in Canada,41 Spain,61 France,62and Japan.63

Regarding specific treatment interventions, the most commonly compared procedures were RALRP versus RRP (10 studies).54,56,64-71 The remaining studies compared the following:

- RP versus EBRT38,41,55
- RP versus observation72,73
- RRP versus 3D-CRT versus BT61
- RRP versus LRP74
- RP versus EBRT (3D-CRT or IMRT) versus BT37,75
- RP versus EBRT versus BT40
- RRP versus RALRP versus LRP70
- BT plus EBRT versus BT plus ADT76
- BT plus IMRT vs. IMRT77
- RP versus robotic RP versus cryotherapy versus BT71
- ADT versus observation78
- ADT versus RP79
- BT versus cryotherapy57
- BT versus image guided-EBRT versus high-dose-rate EBRT80
- IMRT versus 3D-CRT81
- IMRT versus proton beam therapy versus 3D-CRT58
- BT versus BT plus ADT82,83
- BT versus EBRT versus BT plus EBRT84
- EBRT versus observation or WW59
- EBRT versus BT versus conservative management (observation)60
- RP versus EBRT versus observation38,42 or WW36
- RP (RRP or LRP or RALRP) versus EBRT (3D-CRT or IMRT) versus BT85
- RRP versus LRP versus RALRP56
- RALRP versus LRP62
- IGRT versus BT86
- RP versus EBRT versus ADT39
- RRP versus 3D-CRT87
- 3D-CRT versus IMRT versus BT versus EBRT plus BT88
- HIFU versus HIFU plus ADT63
- BT versus BT plus IMRT89
- RP versus RP plus radiation versus EBRT versus EBRT plus BT versus BT versus radiation90

A great deal of variability existed in the level of detail provided on treatment techniques in the nonrandomized comparative studies. As noted above, studies employed several variations of RP, from open to robot-assisted laparoscopic and with or without nerve-sparing techniques. The only study to describe how cryotherapy was delivered reported that it was delivered with a third-generation delivery system.71 BT was delivered using a variety of methods, including the following:

- Intraoperative treatment planning with ultrasound guidance with a median dose of 14,400–14,500 cGy75
- Either a high-dose or low-dose rate77,80
- Either iodine 125 or palladium 103^82^
- A modified peripheral loading dose rate technique with permanent palladium seeds delivering an average of 125 Gray (Gy) dose71

Two studies provided details about how EBRT was delivered. In one study, EBRT was delivered at a median dose of 7,400–7,800 cGy; in the other study75 it was delivered at a median dose of 78 Gy (range 59.4 to 81.5) at 2 Gy per fraction.37 One study reported the use of a ultra-high-dose IMRT using a five- to seven-field IMRT plan with 15MV photons to a dose of 86.4 Gy in 48 fractions of 1.8 Gy.77 Study selection criteria and description of treatment appear in Table D-2 of Appendix D.

To be included in this report, a study must have enrolled a minimum of 85 percent of patients with clinically localized prostate cancer clinical T stage T1 through T3a and have reported results separately for these patients compared with patients with higher T stages. Six studies did not report Gleason scores,57,58,66,73,78,84 seven studies did not report PSA levels,58,59,66,67,72,78,81 and four studies,58,66,73,78 did not report either Gleason scores nor PSA levels.

Eleven studies had an outcome measure of all-cause mortality,36-40,61,65,73,78,79,82 17 studies had an outcome measure of prostate cancer–specific mortality,37-42,59,68,72,73,75,76,78,79,84,86,87 five studies had an outcome measure of overall survival,42,72,75,78,86 six studies reported biochemical failure,36,56,62,65,86,88 13 studies reported biochemical progression–free survival,54,62-65,67-70,74,86,89,91 and three studies reported progression to metastasis,65,68,88 and 19 studies reported QOL and/or adverse events.37,55,57,58,62,63,65,66,68,71,77,80,81,83,85,88,90-92 (see Table 15).

Table 15 Overview of nonrandomized comparative studies (44 studies): Key Question 1

Study | Number of Patients | Subjects | Outcomes | Duration
Alemozaffar et al. 2014^68^ | RALRP: 132patients RRP: 468 patients | Mean age at diagnosis: RALRP: 67.2 years RRP: 65.4 years ≥1 of the following: myocardial infarction, coronary artery bypass or coronary angioplasty, confirmed angina, stroke, Parkinson disease, emphysema or chronic bronchitis, or diabetes RALRP: 18.8% Open RRP: 16.8% Median PSA: RALRP: 5.0 ng/mL Open RRP: 5.6 ng/mL | PCSM Progression to metastasis BRFS QOL | A minimum followup of 2 years
Mukherjee et al. 2014^37^ | RP: 5,805 patients EBRT: 2,183 patients BT: 2,936 patients | Median age at diagnosis (range): RP: 60 years (37–87) EBRT: 69 years (40–87) BT: 67 years (41–88) Median (range) PSA ng/mL: RP: 5.6 (0.03–228.5) EBRT: 9.1 (0.37–692.9) BT: 6.0 (0.18–82.91) Gleason: RP: ≤6: 60.4% 7: 30.8% ≥8: 7.7% Unknown: 1.1% EBRT: ≤6: 47.3% 7: 35.3% ≥8: 16.8% Unknown: 0.7% BT: ≤6: 58.5% 7: 36.4% ≥8: 5.0% Unknown: 0% | All-cause mortality PCSM Adverse events | 3.05 years median followup
DeGroot et al. 2013^41^ | RP: 458 patients (cohort) RP: 36 patients (cases) EBRT: 518 patients (cohort) EBRT: 78 patients (cases) | RP cohort: Mean age (SD): 62.8 years (6.1) PSA: ≤4: 12.5% >4 to ≤10: 57.0% >10 to ≤20: 30.6% Gleason score: 2–4: 23.6% 5–6: 53.3% 7: 23.1% RP cases Mean age (SD): 62.1 years (5.8) PSA <4: 13.9% >4 to <10: 38.9% >10 to <20: 47.2% Gleason score 2–4: 16.7% 5–6: 52.8% 7: 30.6% EBRT cohort Mean age (SD): 69.2 years (5.6) PSA <4: 15.8% >4 to <10: 43.8% >10 to <20: 40.4% Gleason score 2–4: 28.2% 5-6: 48.5% 7: 23.4% EBRT cases Mean age (SD):67.7 years (5.7) PSA <4: 10.3% >4 to <10: 46.2% >10 to <20: 43.6% Gleason score 2–4: 23.1% 5–6: 38.5% 7: 23.1% | PCSM | Median followup 4.25 years
Ferrer et al. 2013^91^ and Ferrer et al. 2008^61^ | RRP: 193 patients 3D-CRT: 194 patients BT: 317 patients | RRP Mean age (SD): 67.6 years (5.2) Mean PSA level (SD): 7.4 (2.7) Mean Gleason score (SD): 5.8 (0.8) 3D-CRT Mean age (SD): 67.1 years (5.2) Mean PSA level (SD): 7.0 (2.7) Mean Gleason score (SD): 5.3 (0.8) BT Mean age (SD): 66.9 years (5.2) Mean PSA level (SD): 6.8 (2.7) Mean Gleason score (SD): 5.1 (0.8) | All-cause mortality BPFS QOL | 2- and 5-year followup
Hoffman et al. 2013^38^ | RP: 1,164 patients EBRT: 491 patients | RP Median age (IQR): 64 years (59–68) PSA <4.0: 9.8% 4.0–10.0: 61.0% >10.0: 29.2% Gleason score 2–4: 63.9% 5–7: 18.2% 8–10: 6.5% Unknown: 11.4% EBRT Median age (IQR): 69 years (64–71) PSA <4.0: 9.4% 4.0–10.0: 55.9% >10.0: 34.7% Gleason score: 2–4: 59.3% 5–7: 22.1% 8–10: 9.6% Unknown: 8.9% | All-cause mortality PCSM | 15-year followup
Liu et al. 2013^79^ | RP: 1,624 patients ADT: 1,624 patients | RP PSA Low (≤10): 51.79% Median (11–20): 7.76% High (>20): 3.26% Positive: 22.91% Unknown: 14.29% Gleason score risk group: Moderately/well differentiated (Gleason score 2–7): 50.86% Poorly differentiated (Gleason score 8–10): 49.14% ADT PSA Low (≤10): 51.79% Median (11–20): 7.76% High (>20): 3.26% Positive: 22.91% Unknown: 14.29% Gleason score risk group: Moderately/well differentiated (Gleason score 2–7): 50.12% Poorly differentiated (Gleason score 8–10): 49.88% | All-cause mortality PCSM | Median followup of 2.95 years and 2.87 years, respectively.
Marina et al. 2013^86^ | IGRT: 734 BT: 282 patients | IGRT Median age (range): 71 years (47–91) Mean PSA (range): 5.9 (0.1–19.7) PSA <10: 576 (78%) 10–20: 158 (22%) Gleason score <6: 96 (13%) 3+4: 443 (61%) 4+3: 190 (26%) Intermediate risk factors 1=Gleason 7: 499 (68%) 1=PSA >10 ng/mL: 72 (10%) 1=T2b–c stage: 21 (3%) 2: 132 (18%) 3: 10 (1%) BT Median age (range): 66 years (40–83) Mean PSA (range): 6.6 (1.4–19.6) PSA <10: 207 (73%) 10–20: 75 (27%) Gleason score <6: 60 (23%) 3+4: 126 (48%) 4+3: 77 (29%) Intermediate risk factors, n (%) 1=Gleason 7: 146 (52%) 1=PSA >10 ng/mL: 27 (10%) 1=T2b–c stage: 25 (9%) 2: 74 (26%) 3: 10 (4%) | Overall survival Cause-specific mortality Biochemical failure BRFS Clinical progression | Median followup was 3.7 years for the IGRT group and 8.0 years for the BT group.
Nepple et al. 2013^40^ | RP: 4,459 patients EBRT: 1,261 patients BT: 972 patients | RP Median age: 60 years Median PSA level: 6.96 Gleason score 5–6: 74% 7: 22% 8–10: 4% EBRT Median age: 68.3 years Median PSA level:11.1 Gleason score 5–6: 55% 7: 33% 8–10: 12% BT Median age: 66.8 years Median PSA level: 6.66 Gleason score 5–6: 83% 7: 17% 8–10: 0.5% | All-cause mortality PCSM | Median 7.2-year followup
Pierorazio et al. 2013^70^ | RRP: 743 patients RALRP: 105 patients LRP: 65 patients | RRP Median age (range): 60 years (38–74) PSA median level (range): 6.65 (0.2–97) Gleason score 5–6: 19.1% 7: 40.7% 8: 25.8% 9–10: 14.5% RALRP Median age (range): 62 years (41–76) PSA median level (range): 6.4 (2.4–45) Gleason score 5–6: 29.8% 7: 35.6% 8: 22.1% 9–10: 12.5% LRP Median age (range): 60 years (43–74) PSA median level (range): 6.7 (1.6–50) Gleason score 5–6: 30.8% 7: 38.5% 8: 21.5% 9–10: 9.2% | BPFS | 3-year followup
Resnick et al. 2013^55^ | RRP: 1,164 patients Radiotherapy: 491 patients | RRP Median age: 64 years Gleason score 2–4: 63.9% Radiotherapy Median age 69 years Gleason score 2–4: 63.9% | QOL | 15-year followup
Silberstein et al. 2013^67^ | RRP: 961 patients RALRP: 493 patients | RRP Median age (IQR): 5 years (4–8) Gleason score ≤6: 39% 7: 48% ≥8: 13% RALRP Median (IQR): 5 (4–7) Gleason score ≤6: 34% 7: 55% ≥8: 11% | BPFS | 3-year followup
Spratt et al. 2013^77^ | IMRT plus BT: 400 patients IMRT: 470 patients | IMRT plus BT Median (IQR) age: 67 (62–72) Gleason score ≤6: 10% 7: 90% IMRT Median (IQR) age: 70 (64–74) Gleason score ≤6: 13% 7: 87% | AEs | Median: 5.3 years
Wirth et al. 2013^74^ | RRP: 600 patients LRP: 244 patients | RRP Age, median (IQR): 59 years (54–64) PSA, median level (IQR): 5.0 (3.8–6.8) Gleason score ≤6: 407 (67.9%) 7: 107 (28.3%) ≥8: 23 (3.8%) T stage T2: 516 (86.0%) T3: 84 (14.0%) LRP Age, median (IQR): 59 years (55–63) PSA, median level (IQR): 5.0 (3.8–6.8) Gleason score ≤6: 166 (68.1%) 7: 72 (29.8%) ≥8: 6 (2.5%) T stage T2: 213 (87.3%) T3: 31 (12.7%) | BPFS | Median followup of 6.6 years and 4.6 years, respectively
Abdollah et al. 2012^59^ | EBRT: 46,521 patients Observation: 22,276 patients | EBRT Age 65–69 years: 24.1% 70–74 years: 41.4% 75–80 years: 34.5% Gleason score <6: 5.5% 6–7: 67.8% 8–10: 26.7% Observation Age 65–69 years: 21.8% 70–74 years: 34.0% 75–80 years: 44.2% Gleason score <6: 17.5% 6–7: 67.6% 8–10: 14.8% | PCSM | 10-year followup
Abern et al. 2012^90^ | RP: 126,042 patients RP and radiation: 15,686 patients EBRT: 83,110 patients EBRT plus BT: 17,338 patients BT: 32,198 patients Radiation not otherwise specified: 826 patients | Age: not reported For total sample: Well differentiated: 14,861 patients Moderately differentiated: 183,558 patients Poorly differentiated: 76,230 patients Undifferentiated: 550 patients | AEs | Median followup 5.42 years (IQR 3 8.33 years) for entire cohort and 98 months for patients that developed bladder cancer
Barry et al. 2012^66^ | RALRP: 406 patients RRP: 220 patients | RALRP 66–69 years: 41.1%; 70–74 years: 43.8%; 75 years or older: 15.0% RRP 66–69 years: 38.2%; 70–74 years: 46.4%; 75 years or older: 15.5% | QOL | 1.67 years
Kibel et al. 2012^75^ | RP: 6,485 patients, 2,843 at site 1 and 3,642 at site 2 3D-CRT plus IMRT: 2,264 patients, 1,638 at site 1 and 626 at site 2 BT: 1,680 patients, 1,330 at site 1 and 350 at site 2 | RP Median age at site 1, 2: 60 years and 61 years bGS 2–6 at site 1, 2: 70% and 76% 3D-CRT plus IMRT Median age at site 1, 2: 69 years and 70 years bGS 2–6 at site 1, 2: 47% and 61% BT Median age site 1, 2: 68 years and 69 years bGS 2–6 at site 1, 2: 81% and 89% | Overall survival PCSM | 10-year followup
Masterson et al. 2012^69^ | RRP: 357 patients RALRP: 669 patients | Age at time of surgery: 61 Gleason sum (%) 5: 105 (10%) 6: 378 (37%) 7: 480 (47%) 3+4: 373 (78%) 4+3: 107 (22%) 8: 15 (1%) 9: 48 (5%) 10: 1 (<1%) | BDFS | 5 years
Mohammed et al. 2012^80^ | BT: 417 patients (HDR=210, LDR=207) EB-IGRT: 1,039 patients EBRT plus HDR- BT: 447 patients | BT Mean age: 64.9 years Gleason score 4–6: 89% EB-IGRT Mean age: 70.8 years Gleason score 4–6: 53% EBRT plus HDR Mean age: 67.1 years Gleason score 4–6: 36% | AEs | Median 4.8-year followup
Nanda et al. 2012^83^ | Low-risk: BT without neoadjunctive HT 3,517 patients BT with neoadjunctive HT: 1,924 patients Intermediate-risk: BT without neoadjunctive HT 2,225 patients BT with neoadjunctive HT 2,140 patients High-risk: BT without neoadjunctive HT: 353 patients BT with neoadjunctive HT 1,007 patients Supplemental EBRT was used in 31% of the total sample | All patients Median age 71 years (IQR 66–75 years) Median PSA in ng/mL (IQR) Low-risk without HT: 6.0 (4.8–7.4) Low-risk with HT: 6.1 (4.9–7.6) Intermediate-risk without HT: 9.5 (6.2–12.1) Intermediate-risk with HT: 9.1 (6.0–12.4) High-risk without HT: 20.0 (8.2–26.7) High-risk with HT: 14.9 (7.2–27.0) Gleason score: Low-risk without HT: ≤6: 100% Low-risk with HT: ≤6: 100% Intermediate-risk without HT: ≤6: 42.8% 7: 57.2% Intermediate-risk with HT: ≤6: 38.5% 7: 61.5% High-risk without HT: ≤6: 31.7% 7: 17% 8–10: 51.3% High-risk with HT: ≤6: 18.3% 7: 22.4% 8–10: 59.3% | AEs | Median followup for low-, intermediate-, and high-risk patients was 4.1 years, 4.4 years, and 4.6 years respectively.
Ploussard et al. 2012^62^ | LRP: 1377 patients RALRP: 1,009 patients | LRP Mean age 62.7 years Mean number of positive cores: 3.9 Biopsy Gleason score % 6: 65.7% 7: 29.4% 8–10: 4.9% RALRP Mean age 62.7 years Mean number of positive cores: 4.5 Biopsy Gleason score % 6: 60.1% 7: 33.0% 8–10: 6.9% | BRFS Biochemical recurrence QOL AEs | Mean followup LRP: 3.25 years RALRP: 1.28 years
Rosenberg et al. 2012^76^ | BT plus EBRT: 186 patients BT plus ADT: 621 patients | BT plus EBRT Median age: 67.8 years Gleason score ≤6: 24 (12.9%) 3+4: 97 (52.1%) 4+3: 65 (34.9%) BT plus ADT Median age: 72.5 years Gleason score ≤6: 254 (40.9%) 3+4: 252 (40.5%) 4+3: 115 (18.5%) | PCSM | 4.4- and 4.8-year followup, respectively
Sheets et al. 2012^58^ | IMRT: 6,666 patients 3D-CRT: 6,310 patients PBT: 685 patients | IMRT Age at diagnosis: 66–69 years: 1,338 (20.1%) 70–74 years: 2,415 (36.2%) 75 years or older: 2,913 (43.7%) Tumor grade well/moderately differentiated: 3,390 (50.9%) 3D-CRT Age at diagnosis: 66–69 years: 1,265 (20.1%) 70–74 years: 2,345 (37.2%) 75 years or older: 2,700 (42.8%) Tumor grade well/moderately differentiated: 3,850 (61.0%) PBT Age at diagnosis: 66–69 years: 248 (36.2%) 70–74 years: 233 (34.0%) 75 years or older: 204 (29.8%) Tumor grade well/moderately differentiated: 413 (60.3%) | AEs | Median followup for the IMRT vs. 3D-CRT was 3.67 years and 5.33 years, respectively. Median followup for IMRT vs. PBT was 3.83 years and 4.17 years, respectively.
Shen et al. 2012^84^ | BT: 910 patients BT plus EBRT: 2,466 patients EBRT: 9,369 patients | BT Median age: 70 years T stage T1: 37.4% T2: 59.2% T3: 3.4% BT plus EBRT Median age: 70 years T stage T1: 26.0% T2: 68.6% T3: 5.4% EBRT Median age: 72 years T stage T1: 22.4% T2: 66.8% T3: 10.8% | PCSM | Median 6.4-year followup
Zelefsky et al. 2012^89^ | BT: 942 patients BT + IMRT: 524 patients | BT PSA <10: 877 10-20: 63 >20: 2 Gleason score <7: 824 7: 114 >7: 4 T stage T1c: 761 T2a: 149 T2b: 25 T2c: 7 BT plus IMRT PSA <10: 432 10–20: 81 >20: 11 Gleason score <7: 135 7: 331 >7: 58 T stage T1c: 252 T2a: 171 T2b: 77 T2c: 24 | BPFS | Median followup 4.08 years (range 1–13 years)
Abdollah et al. 2011^72^ | RP: 22,244 patients Observation: 22,450 patients | RP Mean age: 69.8 years Gleason score 2–5: 4.9% 6–7: 68.2% 8–10: 26.9% Observation Mean age: 73.5 years Gleason score 2–5: 17.6% 6–7: 67.6% 8–10: 14.8% | PCSM Other-cause mortality | 10-year followup
Bekelman et al. 2011^81^ | IMRT: 5,845 patients 3D-CRT: 6,753 patients | IMRT Age at diagnosis: 65–74 years: 55% Gleason score 5–7: 70% 3D-CRT Age at diagnosis: 65–74 years: 55% Gleason score 5–7: 68% | AEs | 2-year followup
Kim et al. 2011^60^ | All EBRT: 19,063 patients BT only: 5,338 patients BT + EBRT: 3,687 patients Conservative management: 13,649 patients | Radiation therapy Age at diagnosis: 66–85 years Charlson comorbidity score: 0: 77% 1: 17% ≥2: 6% [underlined: Clinical T stage:] [underlined: T1]: 52% [underlined: T2]: 48% [underlined: Conservative management] Age at diagnosis: 66–85 years Charlson comorbidity score: 0: 71% 1: 18% ≥2: 11% [underlined: Clinical T stage]: [underlined: T1]: 65% [underlined: T2]: 35% | AEs (GI toxicity) | 10 years
Rice et al. 2011^36^ | RP: 194 patients vs. EBRT: 252 patients vs. WW without secondary treatment: 214 patients vs. WW with secondary treatment: 110 patients | RP Mean age at diagnosis: 72.2±1.9 years Mean PSA: 5.3±2.2 ng/mL Clinical T stage T1: 111 (57.2%) Clinical T stage T2a: 83 (42.8%) EBRT Mean age at diagnosis: 74.1±3.1 years Mean PSA: 6.0±2.2 ng/mL Clinical T stage T1: 150 (59.5%) Clinical T stage T2a: 102 (40.5%) WW without secondary treatment Mean age at diagnosis: 75.7±3.8 years Mean PSA: 4.7±2.3 ng/mL Clinical T stage T1: 141 (65.9%) Clinical T stage T2a: 73 (34.1%) WW with secondary treatment Mean age at diagnosis: 74.5±3.6 years Mean PSA: 5.6±2.2 ng/mL Clinical T stage T1: 67 (60.9%) Clinical T stage T2a: 43 (39.1%) | Overall survival BRFS PF survival | RP: 7.2±4.2 years EBRT: 7.0±4.0 years WW without secondary treatment: 5.3±3.2 years WW with secondary treatment: 8.4±3.9 years
Williams et al. 2011^57^ | BT: 9,985 patients Cryotherapy: 943 patients | BT 65–69 years: 3,233 (32.4%) 70–74 years: 3,643 (36.5%) 75 years or older: 3,109 (31.1%) Tumor grade well/moderately differentiated: 84.5% Cryotherapy 65–69 years: 218 (23.1%) 70–74 years: 366 (35.6%) ≥75: 389 (41.3%) Tumor grade well/moderately differentiated: 60.6% | AEs | ≥2 years
Barocas et al. 2010^64^ | RRP: 491 patients RALRP: 1,413 patients | RRP Mean age: 62 years (7.3) Biopsy Gleason score ≤6: 66.6% RALRP Mean age: 61 years (7.3) Biopsy Gleason score ≤6: 69.9% | BRFS | 3 years of followup
Cooperberg et al. 2010^39^ | RP: 5,066 patients EBRT: 1,143 patients ADT: 1,329 patients | RP Median age: 62 years PSA, 0-6: 2,673 (52.8%) 6.01–10: 1,452 (28.7%) 10–20: 698 (13.8%) 20.01–30: 129 (2.6%) >30: 114 (2.3%) Gleason score 2-6: 3,573 (52.8%) 3+4: 850 (16.8%) 4+3: 355 (7%) 8+10: 288 (5.7%) EBRT Median age: 72 years PSA 0–6: 322 (28.2%) 6.01–10: 330 (28.9%) 10–20: 302 (26.4%) 20.01–30: 72 (6.3%) >30: 117 (14.9%) Gleason score 2-6: 619 (54.2%) 3+4: 218 (19.1%) 4+3: 136 (11.9%) 8+10: 170 (14.9%) ADT Median age: 74 years PSA 0–6: 301 (22.7%) 6.01–10: 355 (26.7%) 10–20: 305 (23%) 20.01–30: 126 (9.5%) >30: 242 (18.2%) Gleason score 2-6: 622 (46.8%) 3+4: 247 (18.6%) 4+3: 175 (13.2%) 8+10: 285 (21.4%) | All-cause mortality PCSM | Median followup RP: 3.9 years EBRT: 4.5 years ADT: 3.6 years
Magheli et al. 2010^56^ | RRP: 522 patients LRP: 522 patients RALRP: 522 patients | RRP Mean age: 58.8 (6.1) Mean PSA: 5.4 (3.2) Gleason score ≤6: 71.1% 7: 26.8% 8-9: 2.1% LRP Mean age: 58.4 (6.4) Mean PSA: 5.4 (3.7) Gleason score: ≤6: 74.7% 7: 21.8% 8-9: 3.4% RALRP Mean age: 58.3 (6.3) Mean PSA: 5.4 (3.2) Gleason score: ≤6: 75.5% 7: 21.8% 8–9: 2.7% | Biochemical recurrence | Mean (SD) followup RRP: 2.5 (1.6) years LRP: 1.47 (0.7) years RALRP: 1.3 (0.6) years
Hadley et al. 2010^73^ | RP: 11,936 patients Observation: 5,879 patients | Not reported | All-cause mortality PCSM | Up to 12 years
Dosoretz et al. 2010^82^ | BT: 1,391 patients BT plus ADT: 1,083 patients | BT Median age was 73 years for all patients enrolled. For patients younger than 73 years Gleason score ≤6: 641 (90%) 7: 60 (8%) 8–10: 10 (1%) BT plus ADT Median age was 73 years for all patients enrolled. For patients younger than 73 years Gleason score ≤6: 426 (86%) 7: 54 (11%) 8–10: 15 (3%) | All-cause mortality | Median 4.8-year followup
Malcolm et al. 2010^71^ | RRP: 135 patients RALRP: 447 patients BT: 122 patients Cryotherapy: 81 patients | RRP Mean age (SD): 59 years (7) Gleason score ≤6: 69% RALRP Mean age (SD): 59 years (6) Gleason score ≤6: 60% BT Mean (SD): 66 (7) Gleason score ≤6: 72% Cryotherapy Mean (SD): 71 (7) Gleason score ≤6: 50% | QOL | 3-year followup
Wong et al. 2009^88^ | 3D-CRT: 270 patients IMRT: 314 patients BT: 225 patients EBRT plus BT: 44 patients | 3D-CRT PSA ≤10: 192 (71%) 10.1–20: 52 (19%) ≥20: 26 (10%) Gleason score ≤6: 175 (65%) ≥7: 95 (35%) Risk group Low: 119 (44%) Intermediate: 111 (41%) High: 40 (15%) IMRT PSA ≤10: 238 (76%) 10.1–20: 54 (17%) ≥20: 22 (7%) Gleason score ≤6: 138 (44%) ≥7: 176 (56%) Risk group Low: 109 (35%) Intermediate: 151 (48%) High: 54 (17%) BT PSA ≤10: 193 (86%) 10.1–20: 28 (12%) ≥20: 4 (2%) Gleason score ≤6: 173 (77%) ≥7: 52 (23%) Risk group Low: 158 (70%) Intermediate: 58 (26%) High: 9 (4%) EBRT plus BT PSA ≤10: 29 (65%) 10.1–20: 13 (30%) ≥20: 2 (5%) Gleason score ≤6: 20 (45%) ≥7: 24 (55%) Risk group Low: 14 (32%) Intermediate: 23 (52%) High: 7 (16%) | Biochemical progression Systemic progression AEs | Median followup was 5.17 years, 4.67 years, 4.08 years, and 5.2 years for patients treated with 3D-CRT, IMRT, BT, and EBRT + BT, respectively.
Krambeck et al. 2008^65^ | RRP: 588 patients RALRP: 294 patients | RRP Median age at surgery: 61 years (range 41–77) Gleason score <6: 0 (0%) 6: 441 (75.0%) 7: 133 (22.6%) ≥8: 14 (2.3%) RALRP Median age at surgery: 61 years (38–76) Gleason score <6: 2 (0.7%) 6: 212 (72.1%) 7: 70 (23.8%) ≥8: 10 (3.4%) | All-cause mortality PCSM Other-cause mortality Biochemical failure BPFS Progression to metastases Local recurrence Systemic progression QOL AEs | Median followup was 1.3 years
Lu-Yao et al. 2008^78^ | ADT: 7,867 patients Observation: 11,404 patients | ADT Median age (IQR) 79 years (74–83) Cancer grade: Moderately differentiated: 65.0% Observation Median age (IQR) 77 years (72–81) Moderately differentiated: 83.7% | Overall survival PCSS | Median followup for overall survival was 6.75 years
Sanda et al. 2008^85^ | RP (RRP or LRP or RALRP): 603 patients | Median age (range): 59 years (38–79) Mean PSA (SD), median, range: 6.7 (5.7), 5.5, 0.5–71.6 PSA <4: 126 (21%) 4–10: 399 (66%) >10: 78 (13%) Gleason score <7: 371 (62%) 7: 207 (34%) >7: 25 (4%) Overall cancer severity Low risk: 267 (44%) Intermediate risk: 302 (50%) High risk: 25 (4%) | QOL AEs | Median followup of 2.5 years
Sanda et al. 2008^85^ | EBRT (IMRT or 3D-CRT): 292 patients | Median age (range): 69 years (45–84) Mean PSA (SD), median, range: 9.1 (10.1), 6.3, 0.5–99.3 PSA <4: 46 (16%) 4–10: 177 (61%) >10: 69 (24%) Gleason score <7: 129 (44%) 7: 123 (42%) >7: 40 (14%) Overall cancer severity Low risk: 80 (27%) Intermediate risk: 159 (54%) High risk: 53 (18%) | QOL AEs | Median followup of 2.5 years
Sanda et al. 2008^85^ | BT: 306 patients | Median age (range): 65 years (44–84) Mean PSA (SD), median, range: 5.8 (3.6), 5.1, 0.6–44.0 PSA <4: 67 (22%) 4–10: 217 (71%) >10: 21 (7%) Gleason score <7: 227 (74%) 7: 76 (25%) >7: 2 (1%) Overall cancer severity Low risk: 182 (59%) Intermediate risk: 119 (39%) High risk: 4 (1%) | QOL AEs | Median followup of 2.5 years
Schroeck et al. 2008^54^ | RRP: 435 patients RALRP: 362 patients | RRP Median age 60.3 years Biopsy Gleason score 2–6: 58.8% RALRP Median age 59.2 years Biopsy Gleason score 2–6: 72.2% | Biochemical failure | Mean followup 1.37 and 1.09 years, respectively
Sumitomo et al. 2008^63^ | HIFU: 260 patients HIFU plus ADT: 270 patients | HIFU Median age (SD, range): 67.7 (7.2, 45–88) Mean PSA (SD, range) 9.1 (4.4, 2.3–29.4) Mean Gleason score (SD, range) 6.3 (1.1, 3–10) Risk level Low: 93 Intermediate: 102 High: 65 HIFU plus ADT Median age (SD, range): 68.2 (6.7, 52–85) Mean PSA (SD, range) 11.6 (6.2, 2.8–29.5) Mean Gleason score (SD, range) 6.3 (1.3, 2–10) Risk level Low: 70 Intermediate: 113 High: 87 | BPFS AEs | 3-year followup
Albertsen et al. 2007^42^ | Surgery: 596 patients Radiation: 642 patients Observation: 114 patients | Surgery Median age: 65 years Gleason score 2–4: 3% 5: 5% 6: 53% 7: 27% 8–10: 12% Radiation Median age: 71 years Gleason score 2–4: 3% 5: 6% 6: 46% 7: 25% 8–10: 20% Observation Median age: 70 years Gleason score 2–4: 17% 5: 15% 6: 46% 7: 11% 8–10: 11% | Overall survival PCSM | 13-year followup
D'Amico et al. 2007^87^ | RRP: 660 patients 3D-CRT: 288 patients | RRP Median age (IQR): 67 years (62–71) PSA <4: 146 (22%) >4–10: 372 (56%) >10–20: 99 (15%) >20: 43 (7%) Gleason score <6: 315 (48%) 7: 271 (41%) 8–10: 74 (11%) 3D-CRT Median age (IQR): 72 years (68–76) PSA <4: 16 (6%) >4–10: 147 (51%) >10–20: 81 (28%) >20: 44 (15%) Gleason score <6: 100 (35%) 7: 148 (51%) 8–10: 40 (14%) | PCSM | 7-year followup

Abbreviations: 3D-CRT=Three-dimensional conformal radiation therapy; ADT=androgen-deprivation therapy; AEs=adverse events; bGS=baseline Gleason score; BT=brachytherapy; EB-IGRT=external beam image-guided radiation therapy; EBRT=external beam radiation therapy; HDR=high dose rate; HIFU=high-intenstity focused ultrasound; HT=hormone therapy; IGRT=image-guided radiation therapy; IMRT=intensity-modulated radiation therapy; IQR=interquartile range; LDR=low dose rate; LRP=laparoscopic radical prostatectomy; PBT=proton beam therapy; PCSM=prostate cancer–specific mortality; PCSS=prostate cancer–specific survival; PSA=prostate-specific antigen; QOL=quality of life; RALRP=robotic-assisted laparoscopic radical prostatectomy; RP=radical prostatectomy; RRP=radical retropubic prostatectomy; T=tumor stage; WW=watchful waiting.

##### Risk of Bias

Our risk-of-bias assessments for the 44 nonrandomized comparative studies appear in Table C-2 of Appendix C. Of these 44 nonrandomized studies that applied statistical adjustments for confounding factors, 26 studies36,37,39,41,54,60,63-71,74,76,77,80,82,85-90 used multivariable regression analysis, 15 studies38,40,42,55-57,59,72,75,79,81,83,84,91,92 used propensity score analysis, 2 studies73,78 used instrumental variable analysis, and 1 study58 used propensity scoring and used an instrumental variable as a sensitivity analysis to control for selection bias.

Forty-one of 44 nonrandomized comparative studies were categorized as high risk of bias for all reported outcomes (see Table 10 for risk-of-bias assessment criteria). Although propensity scoring and multivariable regression analysis can reduce the risk of bias from known or observed confounding factors, they cannot reduce the risk of bias from unknown or unobserved confounding factors. Therefore, these techniques cannot reduce the risk of bias to a level that is equivalent to the risk in a well- or moderately well–designed RCT.

The three remaining nonrandomized comparative studies were categorized as medium risk of bias because all used instrumental variable analysis, which effectively “pseudorandomizes” patients into different groups.58,73,78 An instrumental variable is a variable that has a statistically significant association with treatment choice but no association with health outcomes or other variables that might affect health outcomes. Unlike propensity scoring and multivariable analysis, instrumental variable analysis can account for both measured and unmeasured confounders. Although this is not completely equivalent to a true randomization approach, and its effectiveness depends on choosing a variable that demonstrably has the properties noted above, some evidence suggests that it may generate results that are closer to those observed in RCTs than observational studies using other statistical adjustment methods.73

Authors were inconsistent in their method of reporting bladder, bowel, and sexual dysfunction. Some authors described these conditions as a measure of QOL while others treated them as adverse events. We categorized them as QOL for the purpose of this report as there seemed to be more subjectivity in evaluating these conditions compared with others, for example, gastrointestinal toxicities.

##### Findings

All abstracted data for the outcome measures that address this KQ appear in Table F-2 (all-cause mortality), Table F-4 (overall survival), Table F-6 (prostate cancer–specific mortality and cause-specific mortality), Table F-8 (biochemical failure), Table F-10 (biochemical progression–free survival), Table F-12 (progression to metastasis), Table F-14 (QOL), and Table F-16 (reported adverse events) of Appendix F. Table 16 summarizes major findings reported by the non-RCTs and is intended to provide a roadmap to the abstracted data, including the key statistics, for each comparison and reported outcome.

Table 16 Major findings reported by nonrandomized comparative studies for Key Question 1

Treatments Being Compared | Outcome | Evidence Base | Major Findings Reported in the Study | Detailed Results Abstracted
RALRP vs. RRP | All-cause mortality | Krambeck et al.65 | At a median followup time 1.3 years, 0.7% of patients died in the RRP group and 1.4% of patients died in the RALRP group. | Table F-2 of Appendix F
RALRP vs. RRP | PCSM | Krambeck et al.65 Alemozaffar et al.68 | No deaths in either treatment group were attributable to prostate cancer during the study period. No significant difference in number of deaths (0 deaths RALRP, 2 deaths RRP) | Table F-6 of Appendix F
RALRP vs. RRP | Biochemical failure | Krambeck et al.65 | During the study, 32/588 (5.4%) cases of PSA progression were found in the RRP group and 14/294 (4.8%) cases of PSA progression were found in the RALRP group. There were also 5 cases of clinical local recurrence in the RRP group and 3 cases in the RALRP group. The groups were similar on margin positivity. | Table F-8 of Appendix F
RALRP vs. RRP | Biochemical progression–free survival | Krambeck et al.65, Barocas et al.64, Schroeck et al.54, Silberstein et al.67 Alemozaffar et al.68 Masterson et al.69 Pierorazio et al.70 | 6 studies did not find a significant between-group difference in biochemical progression–free survival. Pierorazio et al.70 found a significant difference favoring RALRP at a mean followup of 3 years. | Table F-7 in Appendix F
RALRP vs. RRP | Biochemical failure | Magheli et al.56 | No difference was found in the RRP-vs.-LRP comparison or the RRP-vs.-RALRP comparison. | Table F-8 of Appendix F
RALRP vs. RRP | Progression to metastasis | Krambeck et al.65 Alemozaffar et al.68 | In 1 study, 1 patient in the RALRP progressed to metastasis during the study. In the other study, 4 patients, all in the RRP group, progressed to metastases. | Table F-12 of Appendix F
RALRP vs. RRP | Adverse events | Krambeck et al.65 | Wound herniation was more common after RALRP than with RRP, and development of bladder neck contracture was more common after RRP than with RALRP. | Table F-16 of Appendix F
RALRP vs. RRP | QOL | Barry et al.66 Krambeck et al.65 Alemozaffar et al.68 Malcolm et al.71 | Barry et al.66 RALRP was found to be associated with greater problems with incontinence. No difference in sexual dysfunction was found between the 2 treatment groups. Krambeck et al.65 and Alemozaffar et al.68 No between-group differences for continence or sexual function. Malcolm et al.71 Could not be determined from data presented. | Table F-14 of Appendix F
LRP vs. RRP | Biochemical progression–free survival | Wirth et al.74 Pierorazio et al.70 | Wirth et al.74 At 6 years, the Kaplan–Meier estimates of survival were 83% and 86% for patients treated by LRP and RRP, respectively (log-rank p=0.18). Pierorazio et al.70 There was a significant difference favoring RRP over LRP at the 3 year followup. | Table F-7 in Appendix F
LRP vs. RRP | Biochemical recurrence | Magheli et al.56 | No significant difference was found. | Table F-8 of Appendix F
RRP vs. 3D-CRT | Overall survival | Ferrer et al.91 | No significant difference at a median followup of 6.02 years. | Table F-4 of Appendix F
RRP vs. 3D-CRT | PCSM | D'Amico et al.87 | At 7-year followup, 29 men (4.45%) in the RRP had died compared with 32 men (11.1%) in the 3D-CRT group (RR 0.4, 95% CI, 0.24 to 0.64). | Table F-6 of Appendix F
RRP vs. 3D-CRT | Biochemical failure | Ferrer et al.91 | At a mean followup of 5.23 years, the relapse rate was significantly higher in the 3D-CRT group (24.7%) than in the RRP group (17.1%). | Table F-7 in Appendix F
RRP vs. 3D-CRT | QOL | Ferrer et al.91 | No significant difference at the 2-year followup on any dimension of QOL as measured by the SF-36, FACT-G, FACT-P, or AUA-7. | Table F-14 of Appendix F
3D-CRT vs. BT | Overall survival | Ferrer et al.91 | At median followup of 6.02 years, no statistically significant difference between the treatment groups was found. | Table F-4 of Appendix F
3D-CRT vs. BT | Progression to metastasis | Wong et al.88 | Percentage distant metastases was 96% and 99% for patients treated with 3D-CRTand BT respectively. | Table F-12 of Appendix F
3D-CRT vs. BT | Biochemical progression-free survival | Ferrer et al.61,91 | Percentage with biochemical relapse at 5.23 years was 24.7% and 16.1% respectively. | Table F-7 in Appendix F
3D-CRT vs. BT | QOL | Ferrer et al.61,91 | A worsening in the EPIC score for sexual function was reported among men who received 3D-CRT (mean change -7.5; 95% CI -12.5 to -2.5).91 However, data were not reported in a way that directly compared 3D-CRT to BT. | Table F-14 of Appendix F
3D-CRT vs. BT | Adverse events (GI toxicity) | Wong et al.88 Kim et al.60 | 1 study reported that BT alone and EBRT + BT caused significantly more grade 2 and 3 acute and late GU toxicity compared with 3D-CRT. The other study reported significantly less GI toxicity in the BT group compared with the 3D-CRT group. | Table F-16 of Appendix F
RP vs. EBRT | All-cause mortality | Nepple et al.40 Rice et al.36 Cooperberg et al.39 Hoffman et al.38 Mukherjee et al.37 Albertsen et al.42 | Nepple et al.40 EBRT was associated with an increase in all-cause mortality compared with RP at median followup of 7.2 years. Rice et al.36 There was no significant difference between RP and EBRT at 6.8-year followup in overall mortality, p=0.18. Cooperberg et al.39 HR 2.21 (95% CI 1.50 to 3.24) in favor of RP at between 3 and 4 year followup visits. Hoffman et al.38 After 15 years of followup, all-cause mortality was more favorable for men who underwent RP than with EBRT (HR 0.35; 95% CI, 0.26 to 0.49) Mukherjee et al.37 All-cause mortality was 3.6% in the RP group and 28.8% in the EBRT group, p<0.001 at 3-year followup. Albertsen et al.42 At an average of 13.3-year followup, RP was associated with improved overall survival compared with overall survival in the radiation group. | Table F-2 of Appendix F
RP vs. EBRT | PCSM | Nepple et al.40 Cooperberg et al.39 Hoffman et al.38 DeGroot et al.41 Mukherjee et al.37 Albertsen et al.42 | Nepple et al.40 At median followup of 7.2 years, EBRT was associated with an increase in PCSM compared with RP. Cooperberg et al.39 HR 1.58 (95% CI 1.32 to 1.89) in favor of RP at between 3- and 4-year followup visits. Hoffman et al.38 After 15 years of followup, PCSM was more favorable for the men who underwent RP than for the men who received EBRT. DeGroot et al.41 At median followup of 51 months, adjusted HRs for risk of prostate cancer death were higher for EBRT compared with RP in the entire study population. HRs were 1.62 (95% CI, 1.00 to 2.61) analyzing by intent-to-treat and 2.02 (95% CI, 1.19 to 3.43) analyzing by treatment received. Mukherjee et al.37 PCSM was 23.7% in the RP group and 28.8% in the EBRT group at 3 year followup. Albertsen et al.42 The prostate cancer mortality ratio was 2.5 times higher (95% CI, 1.7 to 3.5) in EBRT patients compared with RP patients. | Table F-6 of Appendix F
RP vs. EBRT | Adverse events | Mukherjee et al.37 | Myodysplastic syndrome occurred in 6 RP patients and 16 EBRT patients, p=0.35. | Table F-16 of Appendix F
RP vs. EBRT | Biochemical recurrence | Rice et al.36 | HR: 1.38 (95% CI 0.88 to 2.16), no between-group difference for biochemical recurrence at 6.8-year followup. | Table F-8 of Appendix F
RP vs. EBRT | QOL | Sanda et al.85 | At 24 months followup, reported problem (using the EPIC survey): Overall urinary problems: RP, 7%; EBRT, 11% (p=not significant) Overall bowel problems: RP, 1%; EBRT, 11% (p=0.001); Overall sexual problems: RP, 43%; EBRT, 37% (p=not significant) | Table F-14 of Appendix F
RP vs. BT | Overall survival | Kibel et al. 2012^75^ | 10 year overall survival was 88.9% for RP and 81.7% for BT. | Table F-4 of Appendix F
RP vs. BT | All-cause mortality | Nepple et al.40 Mukherjee et al.37 | Nepple et al.40 BT was associated with an increase in all-cause mortality compared with RP at median followup of 7.2 years. Mukherjee et al.37 All-cause mortality at 3 years was 3.6% for RP and 4.6% for BT. | Table F-2 of Appendix F
RP vs. BT | PCSM | Nepple et al.40 Kibel et al.75 Mukherjee et al.37 | Nepple et al.40 At median followup of 7.2 years, there was no statistically significant increase with BT vs. RP. Kibel et al. 2012^75^ 10 year PCSM was 1.8% for RP and 2.3% for BT. Mukherjee et al.37 At 3-year followup, PCSM was 0.9% for RP and 0.6% for BT | Table F-6 of Appendix F
RP vs. BT | Adverse events | Abern et al.90 Mukherjee et al.37 | Abern et al.90 The authors found that patients receiving radiation had a 70% increased risk of subsequent bladder cancer. After BT with or without EBRT the risks were highest. Mukherjee et al.37 Myodysplastic syndrome occurred in 6 RP patients and 9 BT cases patients. | Table F-16 of Appendix F
RP vs. BT | QOL | Sanda et al.85 | Patients in the BT group had significantly more urinary and bowel problems than those treated with RP. There was no between-group difference in sexual problems. | Table F-16 of Appendix F
EBRT vs. BT | All-cause mortality | Mukherjee et al.37 | All-cause mortality was 28.8% in EBRT and 4.6% in BT at 3 year followup. | Table F-2 of Appendix F
EBRT vs. BT | PCSM | Shen et al.84 Mukherjee et al.37 | Shen et al.84 There was a significant difference in PCSM in favor of BT at a median followup of 6.4 years (HR 0.66; 95% CI, 0.49 to 0.86). The 10-year PCSM rate was 21.1% for EBRT and 11.3% for BT alone. Mukherjee et al.37 PCSM was 8.3% in EBRT and 0.6% in BT at 3 year followup. | Table F-6 of Appendix F
EBRT vs. BT | Adverse events | Abern et al.90 Mukherjee et al.37 Wong et al.88 Kim et al.60 | Abern et al.90 The authors found that patients receiving radiation had a 70% increased risk of subsequent bladder cancer. After BT with or without EBRT the risks were highest. Mukherjee et al.37 Myodysplastic syndrome occurred in 16 EBRT patients and 9 BT cases. Wong et al.88 BT caused a lower incidence of acute or late GI toxicity than EBRT. Kim et al.60 BT had a significantly lower rate of GI toxicity than EBRT. | Table F-16 of Appendix F
EBRT vs. BT | QOL | Sanda et al.85 | No treatment-related deaths occurred in either treatment group. There was no significant difference in urinary, bowel or sexual problems. | Table F-16 of Appendix F
EBRT vs. BT | Biochemical failure | Wong et al.88 | 94% in both groups. | Table F-8 of Appendix F
EBRT vs. BT | Distant metastases | Wong et al.88 | 96% for 3D-CRT, 97% IMRT, BT 99%. | Table F-12 of Appendix F
RALRP vs. LRP | Biochemical progression-free survival | Pierorazio et al.70 | 67.8% for RALRP, 41.7% for LRP, but data presentation does not allow determination of statistical significance. | Table F-7 in Appendix F
RALRP vs. LRP | Biochemical recurrence | Magheli et al.56 Ploussard et al.62 | Magheli et al.56 Data were not presented in useable manner. Ploussard et al.62 Biochemical recurrence rates were 18% for LRP and 10.3% for RALRP, a significant difference favoring RALRP. | Table F-8 of Appendix F
RALRP vs. LRP | QOL | Ploussard et al.62 | No significant between-group difference for continence at 1-year followup but by the 2-year followup continence rates favored RALRP. Rates of potency recovery favored RALRP at 1- and 2-year followup periods. | Table F-14 of Appendix F
RALRP vs. LRP | Adverse events | Ploussard et al.62 | Clavien 0–5 adverse events did not differ significantly between groups. Anastomosis leakage occurred significantly more in LRP treated patients. Overall, 6.8% of LRP vs. 10.5% of RALRP patients experienced an event (a nonsignificant difference). | Table F-16 of Appendix F
RP vs. observation | All-cause mortality | Abdollah et al.72 Hadley et al.73 Rice et al.36 Albertsen et al.42 | Abdollah et al.72 RP was associated with a significant reduction in all-cause mortality compared with observation. Hadley et al.73 Using the traditional multivariable survival analysis method or the propensity score adjustment method, the authors found that observation was associated with greater risk of all-cause mortality than was radical prostatectomy. But using the instrumental variable approach, the study found no significant difference between the 2 treatment groups. Rice et al.36 RP vs. WW without secondary treatment p=0.008; RP vs. WW with secondary treatment p=0.44, favoring RP over WW without secondary treatment at 6.8-year followup. Albertsen et al.42 Overall survival rates were 78%, 71%, and 61% for low-, intermediate- and high-risk groups, respectively, for RP for 13-year followup. Comparable rates for observation were 58%, 55%, and 37%, favoring surgery. | Table F-2 of Appendix F
RP vs. observation | PCSM | Abdollah et al.72 Hadley et al.73 Albertsen et al.42 | Abdollah et al.72 RP was associated with a significant reduction in PCSM compared with that outcome in the observation group. Hadley et al.73 Using the traditional multivariable survival analysis method or the propensity score adjustment method, the authors found that observation was associated with greater risk of PCSM than RP. But using the instrumental variable approach, the study did not find a significant difference between the 2 treatment groups. Albertsen et al.42 Cause-specific survival rates were 96%, 92%, and 90% for low-, intermediate- and high-risk groups, respectively, for RP for 13-year followup. Comparable rates for observation were 83%, 89%, and 60%, favoring surgery. | Table F-6 of Appendix F
RP vs. observation | Biochemical recurrence | Rice et al.36 | RP vs. WW without secondary treatment p=0.01 and RP vs. WW with secondary treatment p=0.05, favoring RP over WW without secondary treatment at 6.8-year followup. | Table F-8 of Appendix F
BT vs. BT plus IMRT | Biochemical progression-free survival | Zelefsky et al.89 | Study authors only reported that there was no tumor control advantage with BT or BT + IMRT. | Table F-7 in Appendix F
RRP vs. cryotherapy | QOL | Malcolm et al.71 | Cryotherapy patients had better rates of returning to baseline urinary function than RRP treated patients. Sexual function and bowel function and bother were not significantly different in the 2 treatment groups. | Table F-14 of Appendix F
Cryotherapy vs. BT | QOL | Malcolm et al.71 Williams et al.57 | Malcolm et al. Sexual function was better in the BT group compared with sexual function in the cryotherapy group. Urinary function was better in the cryotherapy group. Bowel function and bother were not significantly different in the 2 groups. Williams et al. Cryotherapy was associated with more urinary and erectile complications but fewer bowel complications than BT. | Table F-14 of Appendix F
Cryotherapy vs. BT | Adverse events | Williams et al.57 | Overall, BT patients had significantly more complications than patients receiving cryotherapy (63.6% vs. 48.8%, respectively, p<0.001). | Table F-16 of Appendix F
RALRP vs. cryotherapy | QOL | Malcolm et al.71 | Cryotherapy patients had better rates of returning to baseline urinary function than RALRP treated patients. Sexual function, bowel function and bother were not significantly different in the 2 groups. | Table F-14 of Appendix F
RALRP vs. BT | QOL | Malcolm et al.71 | BT patients had better rates of returning to baseline urinary function than RALRP treated patients. Sexual function was better in the BT group than sexual function in the RALRP group. Bowel function and bother were not significantly different by treatment group. | Table F-14 of Appendix F
ADT vs. observation | All-cause mortality | Lu-Yao et al.78 | The overall mortality rate was higher in the ADT group than in the observation group. | Table F-2 of Appendix F
ADT vs. observation | PCSM | Lu-Yao et al.78 | The PCSM rate was higher in the ADT group than in the observation group. | Table F-6 of Appendix F
IMRT vs. 3D-CRT | Biochemical failure | Wong et al.88 | The 5-year biochemical failure rates were 74% and 87% for patients treated with 3D-CRT and IMRT, favoring 3D-CRT. | Table F-8 of Appendix F
IMRT vs. 3D-CRT | Progression to metastasis | Wong et al.88 | Percentage distant metastases was 96% and 97% for patients treated with 3D-CRT and IMRT, respectively, with no significant difference between the 2 treatments. | Table F-12 of Appendix F
IMRT vs. 3D-CRT | Adverse events | Bekelman et al.81 Sheets et al.58 Wong et al.88 Kim et al.60 | Bekelman et al.81 IMRT was associated with a reduction in bowel complications and proctitis and hemorrhage compared with 3D-CRT. Sheets et al.58 No significant difference for GI procedures, urinary nonincontinence diagnoses or procedures, urinary incontinence procedures, or erectile dysfunction procedures. Hip fractures occurred significantly more in the 3D-CRT group. Wong et al.88 Acute GI toxicity was similar in both groups. There were more grade 2 acute toxicities (49% vs. 39%) and late (27% vs. 16%) GU toxicities but no increase in grade 3 toxicities from high-dose IMRT vs. conventional 3D-CRT. Kim et al.60 IMRT was associated with a lower rate of GI toxicity than 3D-CRT. | Table F-16 of Appendix F
IMRT vs. 3D-CRT | QOL | Sheets et al.58 | There was no significant between-group difference in urinary incontinence diagnoses. For erectile dysfunction diagnoses, more patients in the IMRT group received this diagnosis, favoring 3D-CRT for this outcome. | Table F-14 of Appendix F
IMRT vs. proton beam therapy | QOL | Sheets et al.58 | There was no significant between-group difference in urinary incontinence diagnoses or erectile function diagnoses. | Table F-14 of Appendix F
IMRT vs. proton beam therapy | Adverse events | Sheets et al.58 Kim et al.60 | In both studies, proton beam therapy was associated with more GI morbidity than IMRT. | Table F-16 of Appendix F
3D-CRT vs. proton beam therapy | QOL | Sheets et al.58 | Urinary incontinence diagnoses occurred at a rate of 3.7 per 100 person-years in the 3D-CRT group and 3.3 in the proton beam therapy group. Erectile dysfunction diagnoses occurred at a rate of 5.3 in the 3d-CRT group vs. 7.4 in the proton therapy group. | Table F-14 of Appendix F
3D-CRT vs. proton beam therapy | Adverse events | Sheets et al.58 Kim et al.60 | Sheets et al.58 GI event diagnoses occurred at a rate of 14.7% in the 3D-CRT group and 17.8% in the proton therapy group. Hip fracture occurred in 1% of the 3D-CRT group and 0.7% of the proton therapy group. Kim et al.60 Proton therapy was associated with a higher rate of GI toxicity than was 3D-CRT (HR 2.13, 95% CI 1.45-3.13). | Table F-16 of Appendix F
Proton beam therapy vs. conservative management | Adverse events | Kim et al.60 | Proton beam therapy was associated with greater GI toxicity than conservative management (HR 13.7, 95% CI 9.09-20.8). | Table F-16 of Appendix F
BT vs. BT plus ADT | Adverse events | Nanda et al.83 | Neoadjunctive hormone therapy was associated with a significantly increased risk of all-cause mortality in patients with low-risk prostate cancer compared with patients treated with only BT. This association was not seen in other risk groups. | Table F-16 of Appendix F
BT vs. BT plus EBRT | PCSM | Shen et al.84 | There was no significant difference in PCSM between groups. The 10-year PCSM rate was 11.3% for BT alone, and 13.4% for BT plus EBRT. | Table F-6 of Appendix F
BT vs. BT plus EBRT | QOL | Mohammed et al.80 | Late incontinence greater than or equal to grade 3 occurred in 0.3% of BT group and 1% of EBRT plus BT group. | Table F-14 of Appendix F
BT vs. BT plus EBRT | Adverse events | Abern et al.90 Mohammed et al.80 | Abern et al.90 The authors found that patients receiving radiation had a 70% increased risk of subsequent bladder cancer. After BT with or without EBRT the risks were highest. Mohammed et al.80 Some adverse events which occurred more often with combination therapy included acute dysuria, late urethral stricture, late genitourinary events, and late rectal bleeding. | Table F-16 of Appendix F
BT vs. conservative management | Adverse events | Kim et al.60 | BT was associated with greater GI toxicity than with conservative management (HR 3.62, 95% CI 2.85-4.61). | Table F-16 of Appendix F
Surgery vs. radiation | Adverse events | Abern et al.90 | The authors found that patients receiving radiation had a 70% increased risk of subsequent bladder cancer. After BT with or without EBRT the risks were highest. | Table F-16 of Appendix F
EBRT vs. observation | All-cause mortality | Albertsen et al.42 | The mortality rate ratio was 1.2 (95% CI, 0.9 to 1.5) times higher in the observation vs. radiation group. | Table F-4 of Appendix F
EBRT vs. observation | PCSM | Albertsen et al.42 Abdollah et al.59 | Albertsen et al.42 In the EBRT group at 5-, 10-, and 15-year followup 4%, 9%, and 17% of patients, respectively, died of prostate cancer in the EBRT group. In the observation group the percentage mortality was 6%, 14% and 25% at each time point, respectively. Abdollah et al.59 There was no between-group difference in the clinical effectiveness of observation vs. radiotherapy for patients with low to intermediate risk prostate cancer on 10-year PCSM (4.1% vs. 3.7%, respectively, p=0.10). For patients in the high-risk group, 10-year PCSM was 14.4% in the observation group vs. 8.8% in the radiotherapy group (p=0.001) in favor of radiotherapy. | Table F-6 of Appendix F
RP vs. ADT | Overall survival | Liu et al.79 | The 8-year survival rate was 79.62% among men who underwent RP cohort compared with 43.39% in the ADT group using Kaplan-Meier estimation. In the RP group, the Kaplan-Meier estimate for 3-year and 5-year survival rate was 96.06% and 92.05%, respectively. In the ADT group, 3-year and 5-year survival rates were 89.66% and 74.81%, respectively. | Table F-4 of Appendix F
RP vs. ADT | All-cause mortality | Liu et al.79 Cooperberg et al.39 | Liu et al.79 There were 56 deaths (3.45%) among men who underwent RP compared with 266 deaths (16.38%) in the ADT group. ADT was associated with an increased risk of all-cause mortality. Cooperberg et al.39 Adjusted HR 2.25 (95% CI, 1.86-2.71), indicating increased risk with ADT | Table F-2 of Appendix F
RP vs. ADT | PCSM | Liu et al.79 Cooperberg et al.39 | Liu et al.79 There were 4 deaths (0.25%) among men who underwent RP compared with 60 deaths (3.69%) in the ADT group. ADT was associated with an increased risk of PCSM. Cooperberg et al.39 Adjusted HR 3.22 (95% CI, 2.16 to 4.81), indicating increased risk with ADT | Table F-6 of Appendix F
IGRT vs. BT | Overall survival | Marina et al.86 | Both 5-year and 8-year overall survival rates were higher among men who underwent high-dose rate BT than with IGRT. | Table F-4 of Appendix F
IGRT vs. BT | Cause–specific survival | Marina et al.86 | No difference between the treatment groups in 5- or 8-year cause-specific survival rates. | Table F-6 of Appendix F
IGRT vs. BT | Biochemical failure | Marina et al.86 | No difference between the treatment groups in 5- or 8-year biochemical failure. | Table F-8 of Appendix F
IGRT vs. BT | Biochemical progression–free survival | Marina et al.86 | Both 5-year and 8-year biochemical disease–free survival rates were higher among men who underwent high-dose rate BT than with IGRT. | Table F-7 in Appendix F
IGRT vs. BT | Progression to metastasis | Marina et al.86 | No difference between the treatment groups in 5- or 8-year progression to metastases. | Table F-12 of Appendix F
EBRT vs. ADT | All-cause mortality | Cooperberg et al.39 | The HR for ADT relative to EBRT was 1.45 (95% CI, 1.02 to 2.07) | Table F-2 of Appendix F
EBRT vs. ADT | PCSM | Cooperberg et al.39 | Relative to EBRT, the HR for ADT was 1.43 (95% CI, 1.21 to 1.69). | Table F-6 of Appendix F
3D-CRT vs. BT | Biochemical failure | Wong et al.88 | The 5-year biochemical failure rate was 74%, and 94%, for patients treated with 3D-CRT and BT, respectively. | Table F-8 of Appendix F
3D-CRT vs. BT | Progression to metastases | Wong et al.88 | Percentage distant metastases was 96% and 99% for patients treated with 3D-CRT and BT, respectively. | Table F-12 of Appendix F
3D-CRT vs. BT | Adverse events | Wong et al.88 Kim et al.60 | Wong et al.88 BT caused significantly more grade 2 and 3 acute and late GU toxicity compared with 3D-CRT. Kim et al.60 BT was associated with significantly lower GI toxicity than 3D-CRT (HR 0.62, 95% CI 0.51-0.75). | Table F-16 of Appendix F
3D-CRT vs. conservative management | Adverse events | Kim et al.60 | 3D-CRT was associated with significantly greater GI toxicity than conservative management (HR 5.44, 95% CI, 4.52-6.54) | Table F-16 of Appendix F
IMRT vs. EBRT plus BT | Biochemical failure | Wong et al.88 | The 5-year biochemical failure rate was 87% and 94% for patients treated with IMRT and EBRT + BT, respectively. | Table F-8 of Appendix F
IMRT vs. EBRT plus BT | Progression to metastasis | Wong et al.88 | Percentage distant metastasis was 97% and 97% for patients treated with IMRT and EBRT + BT, respectively. | Table F-12 of Appendix F
IMRT vs. EBRT plus BT | Adverse events | Wong et al.88 | EBRT+ BT caused significantly more grade 2 and 3 acute and late GU toxicity compared with IMRT. | Table F-16 of Appendix F
IMRT vs. BT | Biochemical failure | Wong et al.88 | The 5-year biochemical failure rate was 87% and 94% for patients treated with IMRT and BT, respectively. | Table F-8 of Appendix F
IMRT vs. BT | Progression to metastasis | Wong et al.88 | Percentage distant metastases was 97% and 99% for patients treated with IMRT and BT, respectively. | Table F-12 of Appendix F
IMRT vs. BT | Adverse events | Wong et al.88 Kim et al.60 | Wong et al. BT caused significantly more grade 2 and 3 acute and late GU toxicity than IMRT. Kim et al.60 GI toxicity did not differ significantly between treatments. | Table F-16 of Appendix F
IMRT vs. conservative management | Adverse events | Kim et al.60 | IMRT was associated with greater GI toxicity than conservative management (HR 4.33, 95% CI, 3.32 to 5.63) | Table F-16 of Appendix F
3D-CRT vs. EBRT plus BT | Biochemical failure | Wong et al.88 | The 5-year biochemical failure rate was 74% and 94% for patients treated with 3D-CRT and EBRT + BT, respectively. | Table F-8 of Appendix F
3D-CRT vs. EBRT plus BT | Progression to metastasis | Wong et al.88 | Percentage distant metastases was 96% and 97% for patients treated with 3D-CRTand EBRT + BT, respectively. | Table F-12 of Appendix F
3D-CRT vs. EBRT plus BT | Adverse events | Wong et al.88 | EBRT + BT caused significantly more grade 2 and 3 acute and late GU toxicity compared with 3D-CRT. | Table F-16 of Appendix F
HIFU vs. HIFU plus ADT | Biochemical progression–free survival | Sumitomo et al.63 | 3-year biochemical progression-free survival among whole study population (53.8% vs. 78.0%) | Table F-7 in Appendix F
HIFU vs. HIFU plus ADT | QOL | Sumitomo et al.63 | Transient grade 1 and 2 incontinence: 6 patients (2.3%) vs. 3 patients (1.1%) | Table F-14 of Appendix F
HIFU vs. HIFU plus ADT | Adverse events | Sumitomo et al.63 | Grade 3 or 4 bladder neck/urethra stricture: 39 patients (15.0%) vs. 38 patients (14.1%) Rectourethral fistula: 4 patients (1.5%) vs. 3 patients (1.1%) | Table F-16 of Appendix F
IMRT plus BT vs. IMRT | QOL | Spratt et al.77 | No difference in the percent of patients who retained full potency at the final followup visit. | Table F-14 of Appendix F
IMRT plus BT vs. IMRT | Adverse events | Spratt et al.77 | GI toxicities and GU toxicities were similar for 7-year actuarial followup but were significantly higher in the IMRT plus BT group acutely. | Table F-16 of Appendix F
RP plus radiation vs. RP | Adverse events | Abern et al.90 | The authors found that patients receiving radiation had a 70% increased risk of subsequent bladder cancer. After BT with or without EBRT, the risks were highest. | Table F-16 of Appendix F
RP vs. EBRT plus BT | Adverse events | Abern et al.90 | The authors found that patients receiving radiation had a 70% increased risk of subsequent bladder cancer. After BT with or without EBRT, the risks were highest. | Table F-16 of Appendix F
RP vs. EBRT | Adverse events | Abern et al.90 | The authors found that patients receiving radiation had a 70% increased risk of subsequent bladder cancer. After BT with or without EBRT the risks were highest. | Table F-16 of Appendix F
EBRT plus BT vs. radiation NOS | Adverse events | Abern et al.90 | The authors found that patients receiving radiation had a 70% increased risk of subsequent bladder cancer. After BT with or without EBRT, the risks were highest. | Table F-16 of Appendix F
EBRT vs. radiation NOS | Adverse events | Abern et al.90 | The authors found that patients receiving radiation had a 70% increased risk of subsequent bladder cancer. After BT with or without EBRT, the risks were highest. | Table F-16 of Appendix F
EBRT vs. EBRT plus BT | PCSM | Shen et al.84 | There was a significant difference in PCSM in favor of BT plus EBRT at a median followup of 6.4 years (HR 0.77; 95% CI, 0.66 to 0.90). The 10-year prostate cancer–specific mortality rate was 21.1% for EBRT and 13.4% for BT plus EBRT. | Table F-6 of Appendix F
EBRT vs. EBRT plus BT | Adverse events | Abern et al.90 | The authors found that patients receiving radiation had a 70% increased risk of subsequent bladder cancer. After BT with or without EBRT, the risks were highest. | Table F-16 of Appendix F
3D-CRT plus IMRT vs. BT | Overall survival | Kibel et al.75 | Adjusted 10-year survival rates were 82.6% and. 81.7%, respectively. | Table F-4 of Appendix F
3D-CRT plus IMRT vs. BT | PCSM | Kibel et al.75 | Adjusted 10-year PCSM 2.9% and 3%, respectively. | Table F-6 of Appendix F
RP vs. 3D-CRT plus IMRT | Overall survival | Kibel et al.75 | HR with RP as referent is 1.6 (95% CI, 1 to 1.9), adjusted 10-year overall survival was 88% for RP and 82.6% for 3D-CRT plus IMRT | Table F-4 of Appendix F
RP vs. 3D-CRT plus IMRT | PCSM | Kibel et al.75 | Adjusted 10-year PCSM was 1.8% and 2.9%, respectively, HR 1.5 (95% CI, 1.0 to 2.3) | Table F-6 of Appendix F
RRP vs. radiotherapy NOS | QOL | Resnick et al.55 | No-control or frequent urinary leakage was significantly higher at the 2- and 5-year followup for RRP treated patients but by the 15-year followup this significant difference disappeared. The same pattern held for erectile dysfunction, with RRP treated patients faring worse. Bowel urgency was significantly worse for the radiotherapy group at the 2- and 5- year followup but this significant between-group difference ceased by the 15-year followup visit. | Table F-14 of Appendix F
BT vs. EB-IGRT | QOL | Mohammed et al.80 | Late incontinence greater or equal to grade 3 was 0.3% for BT and 0.4% for EB-IGRT | Table F-14 of Appendix F
BT vs. EB-IGRT | Adverse events | Mohammed et al.80 | The incidence of any acute grade 2 or higher GI or GU toxicities was lower in the BT group. Dysuria was most common among men who received BT alone. Rectal bleeding occurred at a higher rate in the EB-IGRT group. | Table F-16 of Appendix F
EB IGRT vs. EBRT plus BT | QOL | Mohammed et al.80 | Late incontinence greater or equal to grade 3 was 0.4% for EB-IGRT and 1% for EBRT plus HDR-BT | Table F-14 of Appendix F
EB IGRT vs. EBRT plus BT | Adverse events | Mohammed et al.80 | The incidence of urethral stricture and urinary retention was higher among men who received EBRT plus HDR-BT. Rectal bleeding occurred at a higher rate in the EB-IGRT group. | Table F-16 of Appendix F
BT vs. BT plus ADT | All-cause mortality | Dosoretz et al.82 | There was a significant between-group difference in rates of all-cause mortality in favor of BT plus ADT (HR 1.24; 95% CI, 1.10 to 1.53). | Table F-2 of Appendix F
RRP vs. BT | Overall survival | Ferrer et al.91 | At median followup of 6.02 years, no statistically significant difference between the treatment groups was found.HR 1.17; 95%, CI 0.47 to 2.94. | Table F-4 of Appendix F
RRP vs. BT | Biochemical recurrence | Ferrer et al.91 | Percentage of patients with biochemical relapse at 5.23 years was 17.1% and 16.1% for RRP and BT, respectively. | Table F-8 of Appendix F
RRP vs. BT | QOL | Ferrer et al.91 | QOL was similar for both groups as measured by SF-36 and AUA-7. For the FACT-G, and FACT-P, there were significant between-group differences with RRP scoring lower on both scales. | Table F-14 of Appendix F

Abbreviations: 3D-CRT=Three-dimensional conformal radiation therapy; ADT=androgen-deprivation therapy; BT=brachytherapy; CI=confidence interval; EB-IGRT=external beam image-guided radiation therapy; EBRT=external beam radiation therapy; EPIC= Expanded Prostate Cancer Index Composite; FACT-G= Functional Assessment of Cancer Therapy–General questionnaire; FACT-P=Functional Assessment of Cancer Therapy–Prostate questionnaire; GI=gastrointestinal; GU=genitourinary; HDR-EBRT=high dose–rate external beam radiation therapy; HIFU=high-intensity focused ultrasound; HR=hazard ratio; IGRT= image-guided radiation therapy; IMRT= intensity-modulated radiation therapy; LRP=laparoscopic radical prostatectomy; NOS=not otherwise specified; PCSM=prostate cancer–specific mortality; QOL=quality of life; RALRP=robotic-assisted laparoscopic radical prostatectomy; RP=radical prostatectomy; RRP=radical retropubic prostatectomy; WW=watchful waiting.

### Conclusions for KQ 1

A summary of the comparisons and outcomes we examined for KQ 1 is in Table 12. The overall evidence based on RCTs alone was sufficient to permit a conclusion for the following treatment comparisons and outcomes:

- Progression to metastases was reduced at 12 years among patients undergoing RP compared to those receiving WW (based on statistically significant differences between interventions in 2 medium risk-of-bias randomized trials).15,25,33,34 (Strength of evidence: moderate.)
- Urinary incontinence (as an indirect measure of QOL) was lower among patients receiving WW than for those undergoing RP (based on 1 medium and 1 high risk-of-bias randomized trial).15,25,33,34 (Strength of evidence: low.)
- Overall survival was higher in 3D-CRT plus ADT treated patients than in patients treated with 3D-CRT alone (based on 1 statistically significant difference between treatments in a single low risk-of-bias randomized study).35 (Strength of evidence: low.)
- All-cause mortality was lower in patients treated with 3D-CRT plus ADT than in patients treated with 3D-CRT alone (based on a statistically significant difference between treatments in a single low risk-of-bias randomized study).35 (Strength of evidence: low.)
- Prostate cancer–specific mortality was lower in patients treated with 3D-CRT plus ADT than in patients treated with 3D-CRT alone (based on a statistically significant difference between treatments in a single low risk-of-bias randomized study).35 (Strength of evidence: low.)

Our strength-of-evidence grades for these patient-oriented outcomes also appear in Table 17 for RCTs across treatment categories and Table 18 from RCTs within treatment categories. The majority of the studies reviewed had medium risk of bias (see the pertinent section above) for objective outcomes and a rating of high for QOL-related outcomes, the only subjective outcomes reported by any of the included studies. Strength of evidence was assessed for overall mortality, overall survival, progression to metastases, prostate cancer–specific mortality and QOL. The strength-of-evidence grades for the nonrandomized comparative studies are reported in Table 19.

Table 17 Key Question 1: Strength-of-evidence grades for randomized controlled trials across primary treatment categories

Comparison | Outcome | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Grade
RP vs. WW33 (1 study, n=695) SPCG-4 trial | All-cause mortality at the end of the 15-year followup period | Medium | Consistency unknown (single study) | Direct | Precise RR 0.75 (95% CI, 0.61 to 0.92) Effect size was statistically significant. | RP | Insufficient
RP vs. WW33 (1 study, n=695) SPCG-4 trial | PCSM at the end of the 15-year followup period | Medium | Consistency unknown (single study) | Direct | Precise RR 0.62 (95% CI, 0.44 to 0.87) Effect size was statistically significant. | RP | Insufficient
RP vs. WW15,25 (2 studies, n=1,426) SPCG-4 trial, PIVOT | All-cause mortality at the end of the 12-year followup period | Medium | Consistent | Direct | Imprecise SPCG-4: RR 0.82 (95% CI, 0.65 to 1.03) PIVOT: HR 0.88 (95% CI, 0.71 to 1.08) Neither effect size was statistically significant. | No significant difference between the interventions | Insufficient
RP vs. WW15,25 (2 studies, n=1,426) SPCG-4 trial, PIVOT | PCSM at the end of the 12-year followup period | Medium | Inconsistent | Direct | Imprecise SPCG-4: RR 0.65 (95% CI, 0.45 to 0.94) PIVOT: HR 0.63 (95% CI, 0.36 to 1.09) 1 effect size was not statistically significant. | RP | Insufficient
RP vs. WW15 (1 study, n=695) SPCG-4 trial | QOL (QOL high) at median followup of 12.2 years (range 7–17) | High | Consistency unknown (single study) | Direct | Imprecise OR: 1.01 (95% CI, 0.65 to 1.58), p=0.96 | No significant difference between the interventions | Insufficient
RP vs. WW15,25 (2 studies, n=1,426) SPCG-4 trial, PIVOT | QOL (urinary leakage at 2–4 year followup) | Medium^a^ | Consistent | Direct | Precise SPCG-4: OR 2.3 (95% CI, 1.6 to 3.2), p <0.001 PIVOT: RR 2.69 (95% CI 1.61 to 4.51), p <0.001 | WW | Low
RP vs. WW15,25 (2 studies, n=1,426) SPCG-4 trial, PIVOT | QOL (erectile dysfunction at 2-4 year followup) | Medium | Inconsistent | Direct | Imprecise SPCG-4: OR: 0.86 (95% CI, 0.64–1.15), p=0.30 PIVOT: RR 1.84 (95% CI, 1.59 to 2.11), p <0.001 | Unclear | Insufficient
RP vs. WW25 (1 study, n=731) PIVOT | QOL (bowel dysfunction at 2 year followup) | Medium | Consistency unknown (single study) | Direct | Imprecise RR 1.08 (95% CI, 0.69 to 1.69), p=0.74 | No significant difference between the interventions | Insufficient
RP vs. WW15 (1 study, n=695) SPCG-4 trial | Progression to metastases at 15 years | Medium | Consistency unknown (single study) | Direct | Precise RR 0.59 (95% CI, 0.45 to 0.79) | RP | Insufficient
RP vs. WW15,25 (2 studies, n=1,426) SPCG-4 trial, PIVOT | Progression to metastases at 12 years | Medium | Consistent | Direct | Precise SPCG-4: RR 0.65 (95% CI, 0.47 to 0.88) PIVOT: HR 0.40 (95% CI, 0.22 to 0.70) | RP | Moderate
RARP vs. LRP45 (1 study, n=120) | QOL (urinary continence, erectile function at 1 year) | High | Consistency unknown (single study) | Direct | Precise Urinary continence: 95% vs. 83.3%, p = 0.042 Erectile function: 80% vs. 54.2%, p=0.02 | RARP | Insufficient
RRP vs. BT44 (1 study, n=200) | QOL at 5-year followup (global health, sexual function, bowel symptoms) | High | Consistency unknown (single study) | Direct | Imprecise (p-value was not statistically significant) | No significant difference between the interventions | Insufficient
EBRT vs. cryotherapy47 (1 study, n=244) | Overall survival | Medium | Consistency unknown (single study) | Direct | Imprecise OR: 0.92 (95% CI 0.41 to 2.05), p=0.84. | No significant difference between the interventions | Insufficient
EBRT vs. cryotherapy47 (1 study, n=244) | PCSM | Medium | Consistency unknown (single study) | Direct | Imprecise OR: 0.79 (95% CI 0.21 to 3.03), p=0.73 | No significant difference between the interventions | Insufficient
EBRT vs. cryotherapy52 (1 study, n=244) | QOL (bowel function) | High | Consistency unknown (single study) | Direct | Imprecise Bowel function scores at 3 years (84.1 vs. 88.1, p=0.092). | No significant difference between the interventions | Insufficient
EBRT vs. cryotherapy52 (1 study, n=244) | QOL (urinary function) | High | Consistency unknown (single study) | Direct | Precise Urinary function scores at 3 years (88.6 vs. 93.0, p=0.043). | Cryotherapy | Insufficient
EBRT vs. cryotherapy52 (1 study, n=244) | QOL (sexual function) | High | Consistency unknown (single study) | Direct | Precise Sexual function scores at 3 years (16.0 vs. 36.7, p<0.001). | EBRT | Insufficient

a The evidence base for this outcome contained one medium and one high risk-of-bias study; because of this borderline between medium and high risk the strength of evidence was lowered from moderate to low.

Abbreviations: BT=Brachytherapy; CI=confidence interval; EBRT=external beam radiation therapy; LRP=laparoscopic radical prostatectomy; OR=odds ratio; PCSM=prostate cancer–specific mortality; PIVOT=Prostate Cancer Intervention Versus Observation Trial; QOL=quality of life; RALRP=robotic-assisted laparoscopic radical prostatectomy; RP=radical prostatectomy; RR=relative risk; RRP=radical retropubic prostatectomy; SOE=strength of evidence; SPCG-4=Scandinavian Prostate Cancer Group Study 4; WW=watchful waiting.

Table 18 Key Question 1: Strength-of-evidence grades for randomized controlled trials within primary treatment categories

Comparison | Outcome | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Grade
RARP vs. LRP45 (1 study, n=120) | QOL (continence recovery at 1 year) | High | Consistency unknown (single study) | Direct | Imprecise 95% vs. 83.3%, p=0.04 by chi-square but p=0.075 (not significant) by Fisher's exact test | RARP | Insufficient
RARP vs. LRP45 (1 study, n=120) | QOL (sexual recovery at 1 year in nerve sparing cohort) | High | Consistency unknown (single study) | Direct | Precise 80% vs. 54.2%, p=0.02 | RARP | Insufficient
RPP vs. RRP46 (1 study, n=200) | QOL (continence recovery at 2 years) | High | Consistency unknown (single study) | Direct | Imprecise (p-value not statistically significant) | No significant difference between the interventions | Insufficient
RPP vs. RRP46 (1 study, n=200) | QOL (erectile function at 2 years) | High | Consistency unknown (single study) | Direct | Precise 60% vs 42%, p=0.032 | RRP | Insufficient
3D-CRT vs. 3D-CRT plus ADT35 (1 study, n=206) | Overall survival at 8-year followup | Low | Consistency unknown (single study) | Direct | Precise Adjusted HR 3.0; 95% CI, 1.5 to 6.4 | 3D-CRT plus ADT | Low
3D-CRT vs. 3D-CRT plus ADT35 (1 study, n=206) | All-cause mortality at median followup of 7.6 years | Low | Consistency unknown (single study) | Direct | Precise HR 1.8 (95% CI, 1.1 to 2.9) (44 vs. 30 deaths) | 3D-CRT plus ADT | Low
3D-CRT vs. 3D-CRT plus ADT35 (1 study, n=206) | PCSM at median 7.6-year followup | Low | Consistency unknown (single study) | Direct | Precise HR 4.1; 95% CI, 1.4 to 12.14 (14 vs. 4 deaths) | 3D-CRT plus ADT | Low
EBRT vs. EBRT plus ADT43 (1 study, n=1,979) | Overall survival at median 9.1-year followup | Medium | Consistency unknown (single study) | Direct | Precise HR 1.17; 95% CI, 1.10 to 1.35 (57% vs. 62% survival rate) | EBRT plus ADT | Insufficient
EBRT vs. EBRT plus ADT43 (1 study, n=1,979) | PCSM at median 9.1-year followup | Medium | Consistency unknown (single study) | Direct | Precise HR 1.87; 95% CI, 1.27 to 2.74 (8 vs. 4 deaths) | EBRT plus ADT | Insufficient
EBRT vs. EBRT plus ADT43 (1 study, n=558, subset of full sample) | QOL (always or almost always functioning sexually) at 1 year | High | Consistency unknown (single study) | Direct | Precise OR: 1.72 (1.17 to 2.52), p=0.004 | EBRT | Insufficient

Abbreviations: ADT=Androgen-deprivation therapy; 3D-CRT=three-dimensional conformal radiation therapy; CI=confidence interval; EBRT=external beam radiotherapy; HR=hazard ratio; LRP= laparoscopic radical prostatectomy; PCSM=prostate cancer–specific mortality; QOL=quality of life; RALRP=robotic-assisted laparoscopic radical prostatectomy; RPP=radical perineal prostatectomy; RRP=radical retropubic prostatectomy; SOE=strength of evidence.

Table 19 Key Question 1: Strength-of-evidence grades for nonrandomized comparative studies

Comparison | Outcome | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Grade
RALRP vs.RRP65 (1 study, n=882) | All-cause mortality | High | Consistency unknown (single study) | Direct | Imprecise | No significant between-group difference | Insufficient
RALRP vs.RRP65,68 (2 studies, n=1,482) | PCSM | High | Consistent | Direct | Imprecise | No significant between-group difference | Insufficient
RALRP vs.RRP65,68 (2 studies, n=1,482) | Progression to distant metastases | High | Consistent | Direct | Imprecise | No significant between-group difference | Insufficient
RALRP vs.RRP65,66,68 (3 studies, n=2,108) | QOL | High | Inconsistent for continence, consistent for sexual dysfunction | Direct | Imprecise | No significant between-group difference for sexual function | Insufficient
RRP vs. 3D-CRT91 (1 study, n=387) | Overall survival | High | Consistency unknown (single study) | Direct | Imprecise | No significant between-group difference | Insufficient
RRP vs. 3D-CRT87 (1 study, n=948) | PCSM | High | Consistency unknown (single study) | Direct | Precise | RRP | Insufficient
RRP vs. 3D-CRT91 (1 study, n=387) | QOL | High | Consistency unknown (single study) | Direct | Imprecise | No significant between-group difference | Insufficient
3D-CRT vs. BT91 (1 study, n=511) | Overall survival | High | Consistency unknown (single study) | Direct | Imprecise | No significant between-group difference | Insufficient
3D-CRT vs. BT88 (1 study, n=495) | Progression to metastases | High | Consistency unknown (single study) | Direct | Imprecise | No significant between-group difference | Insufficient
3D-CRT vs. BT91 (1 study, n=511) | QOL | High | Consistency unknown (single study) | Direct | Imprecise | No significant between-group difference | Insufficient
RP vs. EBRT36-40,42 (6 studies, n=22,771) | All-cause mortality | High | Consistent | Direct | Precise | RP | Low
RP vs. EBRT37-42 (6 studies, n=23,301) | PCSM | High | Consistent | Direct | Precise | RP | Low
RP vs. EBRT85 (1 study, n=895) | QOL | High | Consistency unknown (1 study) | Direct | Precise | RP | Insufficient
RP vs. BT75 (1 study, n=8,165) | Overall survival | High | Consistency unknown (1 study) | Direct | Precise | RP | Insufficient
RP vs. BT37,40 (2 studies, n=14,172) | All-cause mortality | High | Inconsistent | Direct | Imprecise | No between-group difference | Insufficient
RP vs. BT37,40,75 (3 studies, n=22,337) | PCSM | High | Inconsistent | Direct | Imprecise | No between-group difference | Insufficient
RP vs. BT85 (1 study, n=909) | QOL | High | Consistency unknown (1 study) | Direct | Precise for urinary and bowel problems Imprecise for sexual problems | RP | Insufficient
EBRT vs. BT37 (1 study, n=8,741) | All-cause mortality | High | Consistency unknown (1 study) | Direct | Precise | BT | Insufficient
EBRT vs. BT37,84 (2 studies, n=19,020) | PCSM | High | Consistent | Direct | Precise | BT | Insufficient
EBRT vs. BT85 (1 study, n=598) | QOL | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
RALRP vs. LRP62 (1 study, n=2,386) | QOL (urinary, bowel, sexual) | High | Consistency unknown (1 study) | Direct | Precise for continence and sexual function | RALRP | Insufficient
RP vs. observation36,42,72,73 (4 studies, n=131,114) | All-cause mortality | High | Inconsistent | Direct | Imprecise | RP | Insufficient
RP vs. observation42,72,73 (3 studies, n=63,219) | PCSM | High | Inconsistent | Direct | Imprecise | RP | Insufficient
RRP vs. cryotherapy71 (1 study, n=216) | QOL | High | Consistency unknown (1 study) | Direct | Precise for continence Imprecise for sexual and bowel problems | Cryotherapy | Insufficient
Cryotherapy vs. BT57,71 (2 studies, n=11,131) | QOL | High | Consistent on sexual function Inconsistent for bowel problems | Direct | Precise for sexual function | BT | Insufficient
RALRP vs. cryotherapy71 (1 study, n=569) | QOL | High | Consistency unknown (1 study) | Direct | Precise for continence Imprecise for sexual and bowel problems | Cryotherapy | Insufficient
ADT vs. observation78 (1 study, n=19,271) | All-cause mortality | Medium | Consistency unknown (1 study) | Direct | Precise | Observation | Insufficient
ADT vs. observation78 (1 study, n=19,271) | PCSM | Medium | Consistency unknown (1 study) | Direct | Precise | Observation | Insufficient
IMRT vs. 3D-CRT88 (1 study, n=584) | Progression to metastases | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
IMRT vs. 3D-CRT58 (1 study, n=12,976) | QOL | High | Consistency unknown (1 study) | Direct | Precise for sexual function Imprecise for continence | 3D-CRT | Insufficient
IMRT vs. proton beam therapy58 (1 study, n=7,351) | QOL | High | Consistency unknown (1 study) | Direct | Imprecise for continence and sexual function | No between-group difference | Insufficient
3D-CRT vs. proton beam therapy58 (1 study, n=6,995) | QOL | High | Consistency unknown (1 study) | Direct | Imprecise for continence Precise for sexual function | 3D-CRT | Insufficient
BT vs. BT plus EBRT84 (1 study, n=3,376) | PCSM | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
BT vs. BT plus EBRT80 (1 study, n=864) | QOL | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
Surgery vs. radiation42 (1 study, n=1,038) | Overall survival | High | Consistency unknown (1 study) | Direct | Precise | RP | Insufficient
Surgery vs. radiation42 (1 study, n=1,038) | PCSM | High | Consistency unknown (1 study) | Direct | Precise | RP | Insufficient
EBRT vs. observation42 (1 study, n=756) | All-cause mortality | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
EBRT vs. observation42,59 (2 studies, n=69,553) | PCSM | High | Consistent | Direct | Precise | EBRT | Insufficient
RP vs. ADT79 (1 study, n=3,248) | Overall survival | High | Consistency unknown (1 study) | Direct | Precise | RP | Insufficient
RP vs. ADT39,79 (2 studies, n=9,643) | All-cause mortality | High | Consistent | Direct | Precise | RP | Insufficient
RP vs. ADT39,79 (2 studies, n=9,643) | PCSM | High | Consistent | Direct | Precise | RP | Insufficient
RRP vs. BT91 (1 study, n=510) | QOL | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
RRP vs. BT91 (1 study, n=510) | Overall survival | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
EB-IGRT vs. EBRT plus BT80 (1 study, n=1,903) | QOL | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
IGRT vs. BT86 (1 study, n=1,016) | Overall survival | High | Consistency unknown (1 study) | Direct | Precise | BT | Insufficient
IGRT vs. BT86 (1 study, n=1,016) | Cause-specific survival | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
IGRT vs. BT86 (1 study, n=1,016) | Progression to metastases | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
EBRT vs. ADT39 (1 study, n=2,472) | All-cause mortality | High | Consistency unknown (1 study) | Direct | Precise | EBRT | Insufficient
EBRT vs. ADT39 (1 study, n=2,472) | PCSM | High | Consistency unknown (1 study) | Direct | Precise | EBRT | Insufficient
3D-CRT vs. BT88 (1 study, n=495) | Progression to metastases | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
IMRT vs. EBRT plus BT88 (1 study, n=358) | Progression to metastases | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
IMRT vs. BT88 (1 study, n=539) | Progression to metastases | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
3D-CRT vs. EBRT plus BT88 (1 study, n=314) | Progression to metastases | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
HIFU vs. HIFU plus ADT63 (1 study, n=530) | QOL | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
IMRT plus BT vs. IMRT77 (1 study, n=870) | QOL | High | Consistency unknown (1 study) | Direct | Imprecise for potency | No between-group difference | Insufficient
EBRT vs. EBRT plus BT84 (1 study, n=11,835) | PCSM | High | Consistency unknown (1 study) | Direct | Precise | EBRT plus BT | Insufficient
3D-CRT plus IMRT vs. BT75 (1 study, n=3,944) | Overall survival | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
3D-CRT plus IMRT vs. BT75 (1 study, n=3,944) | PCSM | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
RP vs. 3D-CRT plus IMRT75 (1 study, n=9,749) | Overall survival | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
RP vs. 3D-CRT plus IMRT75 (1 study, n=9,749) | PCSM | High | Consistency unknown (1 study) | Direct | Imprecise | No between-group difference | Insufficient
RRP vs. radiotherapy NOS55 (1 study, n=1,655) | QOL | High | Consistency unknown (1 study) | Direct | Precise | Sexual function and incontinence: Radiotherapy NOS Bowel problems: RRP | Insufficient
BT vs. EB-IGRT80 (1 study, n=1,456) | QOL | High | Consistency unknown (1 study) | Direct | Imprecise for incontinence | No between-group difference | Insufficient

Abbreviations: 3D-CRT=Three-dimensional conformal radiation therapy; ADT=androgen-deprivation therapy; BT=brachytherapy; EB-IGRT=external beam image-guided radiation therapy; EBRT=external beam radiation therapy; HIFU=high-intensity focused ultrasound; IGRT=image-guided radiation therapy; IMRT=intensity-modulated radiation therapy; LRP=laparoscopic radical prostatectomy; NOS=not otherwise specified; PCSM=prostate cancer–specific mortality; QOL=quality of life; RALRP=robotic-assisted laparoscopic radical prostatectomy; RP=radical prostatectomy; RRP=radical retropubic prostatectomy; SOE=strength of evidence.

Based on consistent evidence from six nonrandomized comparison studies with high risk of bias, we drew two additional conclusions:

- All-cause mortality was significantly lower in patients treated with RP than in patients treated with EBRT.36-40,42(Strength of evidence: low.)
- Prostate cancer–specific mortality was significantly lower in patients treated with RP than in patients treated with EBRT.37-42 (Strength of evidence: low.)

## Key Question 2 Specific Patient Characteristics Affecting the Outcomes of Prostate Cancer Therapies

In this section, we summarize findings from RCTs and nonrandomized comparative studies that stratified data by patient characteristics (Tables 20–27). Table 20 compares major primary treatment options and reports clinical outcome measures for the RCTs across primary treatment categories. Table 21 compares major primary treatment options and reports clinical outcome measures for the RCTs within primary treatment categories. Table 23 compares major primary treatment options and reports clinical outcome measures for the nonrandomized comparative studies.

Table 20 Overview of randomized controlled trials across primary treatment categories (2 trials): Key Question 2

Study | Interventions and Number of Patients | Patient Characteristics | Outcomes | Duration
Wilt et al. 2012^25^ Prostate Intervention Versus Observation Trial (PIVOT) | RP: 364 patients vs. Observation: 367 patients | Age Race Comorbidity status | All-cause mortality PCSM | Median followup of 10 years
Bill-Axelson et al. 2011^33^ Scandinavian Prostate Cancer Group-4 (SPCG-4) trial | RP: 347 patients vs. WW: 348 patients | Age | All-cause mortality PCSM Progression to metastases | Median followup of 15 years

Abbreviations: PCSM=prostate cancer–specific mortality, RP=radical prostatectomy, WW=watchful waiting.

Table 21 Overview of randomized controlled trials within primary treatment categories (2 trials): Key Question 2

Study | Interventions and Number of Patients | Patient Characteristics | Outcomes | Duration
Jones et al. 2011^43^ | EBRT: 992 patients vs. EBRT plus short-term ADT: 987 patients | Age Race | Overall survival PCSM Biochemical failure | Median followup of 9.1 years
D'Amico et al. 2008^35^ Same study as Nguyen et al. 2010^53^ | EBRT: 104 patients vs. EBRT plus ADT: 102 patients | Comorbidity status | All-cause mortality | Median followup of 7.6 years

Abbreviations: ADT=Androgen-deprivation therapy; EBRT=external beam radiation therapy; PCSM=prostate cancer–specific mortality.

Table 22 Major findings reported by randomized controlled trials for Key Question 2

Treatments Being Compared | Outcome | Evidence Base | Major Findings Reported in the Study | Detailed Results Abstracted
RP vs. observation | All-Cause Mortality | PIVOT Wilt et al.25 | No difference in all-cause mortality was found when stratified according to age (younger than 65 years or 65 years or older), race (white, black, or other), Charlson Comorbidity score (0 or ≥1), self-reported performance status (0, 1–4) or 0=Fully Active; 1=Symptoms but ambulatory and able to do light work, 2=No work but self-care and active 50% of waking hours, 3=Limited self-care, confined to bed or chair >50% of waking hours, 4=Completely disabled. | Table F-1 in Appendix F
RP vs. WW | All-Cause Mortality | SPCG-4 Bill-Axelson et al.15,33,34 | The authors evaluated the interaction between treatment and age (<65 years vs. ≥65 years) and reported a significant reduction in all-cause mortality among men who were <65 years of age treated with RP (p=0.003). | Table F-1 in Appendix F
RP vs. observation | PCSM | PIVOT Wilt et al.25 | No difference in PCSM was found when stratified according to age (<65 years or ≥65 years), race (white, black, or other), Charlson Comorbidity score (0 or ≥1), self-reported performance status between both groups (0, 1–4) or 0=Fully Active, 1=Symptoms but ambulatory and able to do light work, 2=No work but self-care and active 50% of waking hours, 3=Limited self-care, confined to bed or chair >50% of waking hours, 4=Completely disabled. | Table F-5 in Appendix F
RP vs. WW | PCSM | SPCG-4 Bill-Axelson et al.15,33,34 | The authors evaluated the interaction between treatment and age (<65 years vs. ≥65 years) and reported a significant reduction in PCSM among men <65 years treated with RP relative to those treated with WW. | Table F-5 in Appendix F
RP vs. WW | Progression to metastases | SPCG-4 Bill-Axelson et al.15,33,34 | The author evaluated the interaction between treatment and age (<65 years vs. ≥65 years) and reported a significant reduction in progression to metastases among RP treated men in the <65 years age group. | Table F-11 in Appendix F
EBRT vs. EBRT plus ADT | Overall survival | Jones et al.43 | The statistically significant advantage of EBRT plus ADT over EBRT alone in overall survival was observed among the white patients but not among the black patients. When the patients were stratified by age, no statistically significant advantage of EBRT plus ADT over EBRT alone in overall survival was observed among the ≤70 years of age or the >70 years of age category. | Table F-3 in Appendix F
EBRT vs. EBRT plus ADT | PCSM | Jones et al.43 | EBRT plus ADT was associated with significantly lower PCSM in comparison with EBRT alone among the white patients, but not among the black patients. EBRT plus ADT was associated with significantly lower cancer-specific mortality in comparison with EBRT alone among men >70 years of age, but not among men ≤70 years of age. | Table F-5 in Appendix F
EBRT vs. EBRT plus ADT | Biochemical failure | Jones et al.43 | EBRT plus ADT was associated with significantly lower biochemical failure rates in all subgroup analyses (age ≤70, age >70 years, white, and black) in comparison with EBRT alone. | Table F-7 in Appendix F
3D-CRT vs. 3D-CRT plus ADT | All-cause mortality | D'Amico et al.35 Same study as Nguyen et al.53 | Among patients with no or minimal comorbidity, all-cause mortality was higher for the EBRT alone group than for the EBRT plus ADT group. Among men with moderate or severe comorbidity, all-cause mortality was not significantly different between the 2 treatment groups. | Table F-1 in Appendix F

Abbreviations: 3D-CRT=Three-dimensional conformal radiation therapy; ADT=androgen-deprivation therapy; EBRT=external beam radiation therapy; PCSM=prostate cancer specific mortality, PIVOT=Prostate Intervention Versus Observation Trial. RP=radical prostatectomy; SPCG-4= Scandinavian Prostate Cancer Group-4; WW=watchful waiting.

Table 23 Overview of nonrandomized comparative studies (9 studies): Key Question 2

Study | Number of Patients | Patient Characteristics | Outcomes | Duration
Mukherjee et al. 2014^37^ | RP: 5,805 patients vs. EBRT: 2,183 patients vs. BT: 2,936 patients | Age | AEs (myodysplastic syndrome) | Median 3.05 years
DeGroot et al. 2013^41^ | RP: 458 patients (cohort) vs. RP: 36 patients (cases) vs. EBRT: 518 patients vs. (cohort) vs. EBRT: 78 patients (cases) | Comorbidity status | PCSM | Median 51 months' followup
Ferrer et al. 2013^91^ | RRP: 193 patients vs. 3D-CRT: 194 patients vs. BT: 317 patients | Age | Overall survival | Median 6.06-year followup
Hoffman et al. 2013^38^ | RP: 1,164 patients vs. EBRT: 491 patients | Age Comorbidity status | All-cause mortality PCSM | 15-year followup
Wirth et al. 2013^74^ | RRP: 600 patients vs. LRP: 244 patients | Age | BPFS | Median followup of 6.6 years and 4.6 years respectively
Abdollah et al. 2012^59^ | EBRT: 46,521 patients vs. Observation: 22,276 patients | Age Comorbidity status | PCSM | 10-year followup
Kibel et al. 2012^75^ | RP: 6,485 patients 3D-CRT: 2,264 patients BT: 1,680 patients | Age Race Comorbidity status | Overall survival PCSM | 10 year followup
Rice et al. 2011^36^ | RP: 194 patients vs. EBRT: 252 patients vs. WW without secondary treatment: 214 patients vs. WW with secondary treatment: 110 patients | Age Race Comorbidity status | Overall mortality BPFS (active treatment groups), progression-free survival (WW without secondary treatment) | Mean followup time 6.8±4.0 years
Dosoretz et al. 2010^82^ | BT: 1,391 patients vs. BT plus ADT: 1,083 patients | Age | All-cause mortality | Median followup 4.8 years

Abbreviations: 3D-CRT=Three-dimensional conformal radiation therapy; ADT=androgen deprivation therapy; AEs=adverse events; BPFS=biochemical progression–free survival; BT=brachytherapy; EBRT=external beam radiation therapy; LRP=laparoscopic radical prostatectomy; PCSM=prostate cancer–specific mortality; RP=radical prostatectomy; RRP=radical retropubic prostatectomy; WW=watchful waiting.

Table 24 Major findings reported by nonrandomized comparative studies for Key Question 2

Treatments Being Compared | Outcome | Evidence Base | Major Findings Reported in the Study | Detailed Results Abstracted
RP vs. WW with and without secondary treatment | All-cause mortality | Rice et al.36 | Rice et al.36 compared RP, EBRT, and WW with or without secondary treatment and found age was a significant predictor of overall mortality but race was not a significant predictor of overall mortality. Compared to patients with no comorbidities, overall mortality was significantly higher for those with 2 or more comorbidities. | Table F-4 in Appendix F
RP vs. EBRT | Hoffman et al.38 All-cause mortality PCSM DeGroot et al.41 PCSM Mukherjee et al. 2014^37^ AEs Rice et al.36 All-cause mortality | Hoffman et al.38 DeGroot et al.41 Mukherjee et al.37 Rice et al.36 | Hoffman et al.38 For the 2 age groups (55–64 and 65–74 years) analyzed, overall mortality was lower among men who underwent RP compared with EBRT. In the 2 comorbidity categories (men with no comorbidity or with any reported comorbidity) analyzed, all-cause mortality was lower in the RP group than with EBRT. For the 2 age groups (55–64 and 65–74 years) analyzed, PCSM was lower among men who underwent RP than with EBRT. In the 2 comorbidity categories (no comorbidity vs. any comorbidity) analyzed, PCSM was lower in the RP group compared with EBRT. DeGroot et al.41 The study authors reported that they investigated whether the competing risk of death from comorbid illness could explain their findings and found that none of their results were statistically significant. Mukherjee et al.37 compared RP, EBRT, and BT and found advanced age was a significant risk factor for developing MDS. Rice et al.36 compared RP, EBRT, and WW with or without secondary treatment and found age was a significant predictor of overall mortality but race was not a significant predictor of overall mortality. Compared to patients with no comorbidities, overall mortality was significantly higher for those with two or more comorbidities. | Table F-2 in Appendix F
RP vs. 3D-CRT | Overall survival PCSM | Kibel et al.75 | Age, race, and comorbidity status were all significantly related to OS. No between-treatment group differences were noted. Age, race, and comorbidity status were not significantly associated with PCSM. | Table F-4 in Appendix F Table F-6 in Appendix F
BT vs. 3D-CRT | Kibel et al.75 Overall survival PCSM Ferrer et al.91 Overall survival | Kibel et al.75 Ferrer et al.91 | Kibel et al.75 compared RP, 3D-CRT, and BT and found age, race, and comorbidity status were all significantly related to OS. No between-treatment-group differences were noted. Age, race, and comorbidity status were not significantly associated with PCSM. Ferrer et al.91 compared RRP, 3D-CRT, and BT and found no significant effect among treatments when comparing age younger than 65 years vs. 65–70 years (HR 1.96; 95% CI, 0.89 to 4.30). They reported a significant effect when patients younger than 65 years were compared with those older than 70 years: (HR 2.95; 95% CI, 1.34 to 6.47). | Table F-4 in Appendix F Table F-6 in Appendix F
EBRT vs. BT | AEs | Mukherjee et al.37 | Advanced age was a significant risk factor for developing MDS. | Table F-16 in Appendix F
RP vs. BT | Mukherjee et al.37 AEs Kibel et al.75 Overall survival PCSM | Mukherjee et al.37 Kibel et al.75 | Mukherjee et al.37 Compared RP, EBRT, and BT and reported advanced age was a significant risk factor for developing MDS. Kibel et al.75 RP, 3D-CRT, and BT and reported age, race, and comorbidity status were all significantly related to OS. No between-treatment-group differences were noted. Age, race, and comorbidity status were not significantly associated with PCSM. | Table F-16 in Appendix F
LRP vs. RRP | Biochemical progression–free survival | Wirth et al.74 | Age was not a significant prognostic factor in biochemical progression–free survival. | Table F-7 in Appendix F
RRP vs. 3D-CRT | Overall survival | Ferrer et al.91 | Ferrer et al.91 evaluated the effect of age on overall survival at median followup of 6.06 years. The authors reported the following using Cox regression models among treatment groups: Age group younger than 65 years vs. 65–70 years: HR 1.96; 95% CI, 0.89 to 4.30. Age group less than 65 years vs. older than 70 years: HR 2.95; 95% CI, 1.34 to 6.47. | Table F-4 in Appendix F
RRP vs. BT | Overall survival | Ferrer et al.91 | Ferrer et al.91 evaluated the effect of age on overall survival at median followup of 6.06 years. The authors reported the following using Cox regression models among treatment groups: Age group younger than 65 years vs. 65–70 years: HR 1.96; 95% CI, 0.89 to 4.30. Age group younger than 65 years vs. older than 70 years: HR 2.95; 95% CI, 1.34 to 6.47. | Table F-4 in Appendix F
BT vs. BT Plus ADT | All-cause mortality | Dosoretz et al.82 | In the subgroup of men younger than 73 years of age, BT plus ADT was not associated with a significantly increased risk of all-cause mortality. However, BT plus ADT was associated with a significantly increased risk of all-cause mortality in men aged 73 years or older. | Table F-2 in Appendix F
EBRT vs. observation | Abdollah et al.59 PCSM Rice et al.36 Overall mortality, biochemical progression-free survival | Abdollah et al.59 Rice et al.36 | Abdollah et al.59 compared EBRT with observation and found that for all three comorbidity subgroups analyzed (Charlson comorbidity index of 0, 1, and >2), the 10-year PCSM rates were lower among patients who underwent EBRT than among those under observation. For 2 age groups (65–69 and 70–74 years), the 10-year prostate cancer–specific mortality rates were not significantly different between the EBRT and the observation groups. But for the age group of 75–80 years, the 10-year prostate cancer–specific mortality rate was significantly lower for the EBRT group than the observation group. Rice et al.36 found that age and presence of 2 or more comorbidities were significant predictors of overall mortality, but not biochemical progression-free survival. Race was not a significant predictor for any outcome. | Table F-6 in Appendix F

Abbreviations: 3D-CRT=Three-dimensional conformal radiation therapy; ADT=androgen-deprivation therapy; AEs=adverse events, BT=brachytherapy; CI=confidence interval; EBRT=external beam radiation therapy; HR=hazard ratio; LRP=laparoscopic radical prostatectomy; MDS=myelodysplastic syndromes; OS=overall survival; PCSM=prostate cancer–specific mortality, RP=radical prostatectomy, RRP=radical retropubic prostatectomy, WW=watchful waiting.

Table 25 Key Question 2: Strength-of-evidence grades for randomized controlled trials across primary treatment categories

Comparison | Outcome | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Grade
RP vs. WW25 | All-cause mortality for patients (age younger than 65 years [n=93] and 65 years or older [n=261]; white [n=236], black [n=99], other [n=19]; Charlson score 0 [n=168] or ≥1 [n=186]; performance score 0 [n=285] or 1–4 [n=69]) at 10-year followup | Medium | Consistency unknown (single study) | Direct | Imprecise (reported p-values for interaction were not significant for all subgroups) | No significant difference between the interventions for any of the subgroups assessed (age, race, comorbidity status, performance status) | Insufficient for all patient subgroups
RP vs. WW25 | PCSM for patients (age younger than 65 years [n=18] and 65 years or older [n=34]; white [n=37], black [n=12], other [n=3]; Charlson score 0 [n=33] or ≥1 [n=19]; Performance score 0 [n=43] or 1–4 [n=9]) at 10-year followup | Medium | Consistency unknown (single study) | Direct | Imprecise (reported p-values for interaction were not significant for all subgroups) | No significant difference between the interventions for any of the subgroups assessed (age, race, comorbidity status, performance status) | Insufficient for all patient subgroups
RP vs. WW33 | Overall mortality for patients age younger than 65 years at 8- and 12-year followup was approximately doubled among the WW patients compared to the RP treated patients. | Medium | Consistency unknown (single study) | Direct | Precise ARR: 11.4 (3.1 to 19.6) and 18.3 (7.8 to 28.8) for 8- and 12-year followup, respectively. | RP | Insufficient for patient subgroup^*^
RP vs. WW33 | PCSM for patients younger than 65 years at 8- and 12-year followup was approximately doubled in the WW patients compared to RP treated patients. | Medium | Consistency unknown (single study) | Direct | Precise ARR: 8.2 (1.9 to 14.4) and 11.2 (2.6 to 19.8) for 8- and 1-year followup, respectively RR 0.49 (95% CI, 0.31 to 0.79) | RP | Insufficient for patient subgroup^*^
RP vs. WW33 | Progression to metastases for patients younger than 65 years at 8- and 12-year follow was reduced among those treated with RP compared to those treated with WW. | Medium | Consistency unknown (single study) | Direct | Precise ARR: 12.1 (4.0 to 20.1) for 8-year followup and RR 0.52 (0.34 to 0.81), p=0.006 for 12-year followup | RP | Insufficient for patient subgroup^*^

* SOE grading reduced by one level based on subgroup analysis (see methods section for further details).

Abbreviations: ARR=Absolute risk reduction, CI=confidence interval; PCSM=prostate cancer–specific mortality; RP=radical prostatectomy; RR=relative risk; SOE=strength of evidence; WW=watchful waiting.

Table 26 Key Question 2: Strength-of-evidence grades for randomized controlled trials within primary treatment categories

Comparison | Outcome | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Grade
EBRT vs. EBRT plus short-term ADT43 | Overall survival among white patients (n=1,505) at 10-year followup. No significant effect for treatment by age. | Medium | Consistency unknown (single study) | Direct | Precise HR 1.19 (95% CI, 1.01 to 1.41). Effect size was statistically significant. | EBRT plus ADT | Insufficient for patient subgroup
EBRT vs. EBRT plus short-term ADT43 | PCSM among white patients (n=1,505) at 10-year followup. | Medium | Consistency unknown (single study) | Direct | Precise HR 2.33 (95% CI, 1.46 to 3.72). Effect size was statistically significant. | EBRT plus ADT | Insufficient for patient subgroup
EBRT vs. EBRT plus short-term ADT43 | PCSM among patients age older than 70 years (n=1,005) at 10-year followup | Medium | Consistency unknown (single study) | Direct | Precise HR 2.19 (95% CI, 1.31 to 3.64). Effect size was statistically significant. | EBRT plus ADT | Insufficient for patient subgroup
3D-CRT vs. 3D-CRT plus ADT35 | All-cause mortality among patients with no or minimal comorbidities was tripled among those treated with EBRT alone vs. those treated with combination therapy EBRT plus ADT at 7.6-year followup. | Low | Consistency unknown (single study) | Direct | Precise HR 4.2 (95% CI, 2.1 to 8.5). Effect size was statistically significant. | 3D-CRT plus ADT | Insufficient for patient subgroup^*^
3D-CRT vs. 3D-CRT plus ADT35 | All-cause mortality among patients with moderate or severe comorbidity (n=49) at a median followup of 7.6 years was similar between treatment groups. | Low | Consistency unknown (single study) | Direct | Imprecise HR 0.54 (95% CI, 0.27 to 1.10), p=0.08. Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup

* SOE grading reduced by one level based on subgroup analysis (see methods section for further details).

Abbreviations: 3D-CRT=three-dimensional conformal radiotherapy; ADT=androgen-deprivation therapy; CI=confidence interval; EBRT=external beam radiation therapy; HR=hazard ratio; PCSM=prostate cancer–specific mortality; SOE=strength of evidence.

Table 27 Key Question 2: Strength-of-evidence grades for nonrandomized comparative studies

Comparison | Outcome | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Grade
RRP vs. 3D-CRT vs. BT91 | Overall survival among men age group younger than 65 years (n=60) vs. 65–70 years (n=79) | Medium | Consistency unknown (single study) | Direct | Imprecise HR 1.96 (95% CI, 0.89 to 4.30). Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
RRP vs. 3D-CRT vs. BT91 | Overall survival among men age group younger than 65 years (n=60) vs. older than 70 years (n=99) | Medium | Consistency unknown (single study) | Direct | Precise HR 2.95 (95% CI, 1.34 to 6.47). Effect size was statistically significant. | RRP | Insufficient for patient subgroup
BT vs. BT plus ADT82 | All-cause mortality among patients age older than 73 years (n=1,268) at a median followup of 4.8 years | Medium | Consistency unknown (single study) | Direct | Precise HR 1.24 (95% CI, 1.01 to 1.53). Effect size was statistically significant. | BT | Insufficient for patient subgroup
EBRT vs. observation59 | PCSM among men with a Charlson comorbidity score of 0 (n=17,760), 1 (n=11,545), and ≥2 (n=12,667) at 10-year followup | Medium | Consistency unknown (single study) | Direct | Precise 0 comorbidity: HR 0.81 (95% CI, 0.67 to 0.98) 1 comorbidity: HR 0.87 (95% CI, 0.75 to 0.99) ≥2 comorbidities: HR 0.79 (95% CI, 0.65 to 0.96). Effect size was statistically significant in same direction for each subgroup. | EBRT | Insufficient for all patient subgroups
EBRT vs. observation59 | PCSM among men aged 75–80 years (n=17,364) at 10-year followup | Medium | Consistency unknown (single study) | Direct | Precise HR 0.7 (95% CI, 0.59 to 0.80). Effect size was statistically significant | EBRT | Insufficient for patient subgroup
EBRT vs. observation59 | PCSM among men aged 65–69 years (n=9,580) and 70–74 (n=15,028) at 10-year followup | Medium | Consistency unknown (single study) | Direct | Imprecise (p-values were not statistically significant for both age groups) | No significant difference between the interventions | Insufficient for patient subgroup
RP vs. EBRT38 | All-cause mortality among men aged 55–64 years (n=759) at 15-year followup | Medium | Consistency unknown (single study) | Direct | Precise HR 0.41 (95% CI, 0.32 to 0.53). Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. EBRT38 | All-cause mortality among men aged 65–74 years (n=896) at 15-year followup | Medium | Consistency unknown (single study) | Direct | Precise HR 0.41 (95% CI, 0.32 to 0.53). Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. EBRT38 | All-cause mortality among men with no comorbidity (n=672) at 15-year followup | Medium | Consistency unknown (single study) | Direct | Precise HR 0.52 (95% CI, 0.41 to 0.65). Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. EBRT38 | All-cause mortality among men with any reported comorbidity (n=983) at 15-year followup | Medium | Consistency unknown (single study) | Direct | Precise HR 0.67 (95% CI, 0.57 to 0.78). Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. EBRT38 | PCSM among men aged 55–64 years (n=759) at 15-year followup | High | Consistency unknown (single study) | Direct | Precise HR 0.21 (95% CI, 0.13 to 0.36). Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. EBRT38 | PCSM among men aged 65–74 years (n=896) at 15-year followup | High | Consistency unknown (single study) | Direct | Precise HR 0.45 (95% CI, 0.31 to 0.65). Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. EBRT38 | PCSM among men with no comorbidity (n=672) at 15-year followup | High | Consistency unknown (single study) | Direct | Precise HR 0.19 (95% CI, 0.12 to 0.31). Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. EBRT38 | PCSM among men with any reported comorbidity (n=983) at 15-year followup | High | Consistency unknown (single study) | Direct | Precise HR 0.49 (95% CI, 0.34 to 0.72). Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. EBRT41 | PCSM among men with any reported comorbidity (n=1,090) at 51 months' followup | Medium | Consistency unknown (single study) | Direct | Imprecise (p-value was not statistically significant) | No significant difference between the interventions | Insufficient for patient subgroup
RP vs. EBRT vs. WW with and without secondary treatment36 | Overall mortality | High | Consistency unknown (single study) | Direct | Precise for age and comorbidities Imprecise for race | Older age and 2 or more comorbidities predicted worse outcome | Insufficient for patient subgroup
RP vs. 3D-CRT vs. BT75 | Overall survival | Medium | Consistency unknown (single study) | Direct | Precise for age, race, and comorbidities | No differences by treatment group | Insufficient for patient subgroup
RP vs. 3D-CRT vs. BT75 | PCSM | Medium | Consistency unknown (single study) | Direct | Imprecise | No differences by treatment group | Insufficient for patient subgroup

Abbreviations: 3D-CRT=Three-dimensional conformal radiation therapy; ADT=androgen-deprivation therapy; BT=brachytherapy; CI=confidence interval; EBRT=external beam radiation therapy; HR=hazard ratio; PCSM=prostate cancer–specific mortality; RP=radical prostatectomy; RRP=radical retropubic prostatectomy; SOE=strength of evidence; WW=watchful waiting.

### Key Points

RCTs that performed subgroup analyses based on patient characteristics reported the following. In all cases, the strength of evidence was insufficient to allow conclusions.

- At 15-year followup, the Scandinavian Prostate Cancer Group-4 (SPCG-4) trial identified a significant reduction in all-cause mortality, prostate cancer–specific mortality (PCSM) and progression to metastases in the younger-than-65 age category but not in the 65-or-older category.
- At 10-year followup, the Prostate Cancer Intervention Versus Observation Trial (PIVOT) found no significant difference between interventions in all-cause mortality and PCSM in either the younger-than-65 age category or in the 65-or-older age group.
- Among patients with no or minimal comorbidity in a single RCT, all-cause mortality was higher for the EBRT-alone group than for the EBRT-plus-ADT group. Among men with moderate or severe comorbidity, all-cause mortality was not significantly different between the two treatment groups.
- In a single RCT, EBRT plus ADT was associated with a significantly lower PCSM than EBRT alone among men older than 70 years of age, but not among men 70 years of age or younger, and among white patients but not among black patients.

### Detailed Synthesis

#### Randomized Controlled Trials

All abstracted data for the outcome measures that address this KQ appear in Appendix F. Table 22 summarizes major findings reported by the RCTs and is intended to provide a roadmap to the abstracted data, including the key statistics, for each comparison and reported outcome. The strength-of-evidence grades for selected outcomes (overall survival, all-cause mortality, progression to metastases, and QOL) for the studies that address this Key Question are provided in Table 25 (RCTs across primary treatment categories) and Table 26 (RCTs within primary treatment categories).

#### Nonrandomized Comparative Studies

All abstracted data for the outcome measures that address this KQ appear in Appendix F. Table 24 summarizes major findings reported by the non-RCTs and is intended to provide a roadmap to the abstracted data, including the key statistics, for each comparison and reported outcome. The strength-of-evidence grades for the nonrandomized studies that address this Key Question are provided in Table 27. The grades are only for the selected outcomes measures, including overall or prostate cancer–specific mortalities and QOL reported using general health status scores.

## Key Question 3 Provider/Hospital Characteristics Affecting Outcomes of the Therapies

We identified 32 reports that were reviewed for possible inclusion in this report. We found no comparative studies (RCTs or non-RCTs) that examined how provider characteristics influence survival in patients with clinically localized prostate cancer treated with RP compared with another form of RP or RP compared with a nonsurgical treatment. These 32 studies were excluded because they were single-site studies, reported an outcome other than survival, examined management changes but not clinical efficacy, or did not provide any detail on provider characteristics.

We did not identify any studies that addressed this KQ. However, given the diverse readership of this report, we would like to note a landmark U.S. Government Accountability Office report that found a growing concern that financial incentives (a provider characteristic) may continue to drive treatment selection and costs.93

## Key Question 4 Tumor Characteristics Affecting the Outcomes of the Therapies

In this section, we summarize findings from RCTs and the nonrandomized comparative studies that stratified data by tumor characteristics (Tables 28–35). Table 28 compares major primary treatment options and reports clinical outcome measures for the randomized controlled trials across primary treatment categories. Table 29 compares major primary treatment options and reports clinical outcome measures for the RCTs within primary treatment categories. Table 31 compares major primary treatment options and reports clinical outcome measures for the nonrandomized comparative studies.

Table 28 Overview of randomized controlled trials across primary treatment categories (2 trials): Key Question 4

Study | Interventions and Number of Patients | Tumor Characteristics | Outcomes | Duration
Wilt et al. 2012^25^ Prostate Intervention Versus Observation Trial (PIVOT) | RP: 364 patients vs. Observation: 367 patients | PSA level Gleason score Tumor risk | All-cause mortality PCSM | Median followup of 10 years
Bill-Axelson et al. 2011^33^ Scandinavian Prostate Cancer Group-4 (SPCG-4) trial | RP: 347 patients vs. WW: 348 patients | Tumor risk | All-cause mortality PCSM Progression to metastases | Median followup of 15 years

Abbreviations: PCSM=prostate cancer–specific mortality; PSA=prostate-specific antigen, RP=radical prostatectomy; WW=watchful waiting.

Table 29 Overview of randomized controlled trials within primary treatment categories (2 trials): Key Question 4

Study | Interventions and Number of Patients | Tumor Characteristics | Outcomes | Duration
Jones et al. 2011^43^ | EBRT: 992 patients vs. EBRT plus short-term ADT: 987 patients | Age 71 years or younger, T1b, T1c, T2a, T2b, PSA ≤20 ng/mL | Overall survival PCSM Biochemical failure | Median followup of 9.1 years
D'Amico et al. 2008^35^ Same study as Nguyen et al. 2010^53^ | 3D-CRT (104 patients) vs. 3D-CRT plus 6 months of both LHRH and antiandrogen vs. 3D-CRT (73 patients) plus 6 months of both LHRH and less than 6 months of antiandrogen (29 patients) | PSA level Gleason score Tumor stage | Biochemical failure | Median followup 8.2 years

Abbreviations: 3D-CRT=Three-dimensional conformal radiation therapy; ADT=androgen-deprivation therapy; EBRT=external beam radiation therapy; LHRH=luteinizing hormone-releasing hormone, PCSM=prostate cancer specific mortality, PSA=prostate-specific antigen.

Table 30 Major findings reported by randomized controlled trials for Key Question 4

Treatments Being Compared | Outcome | Evidence Base | Major Findings Reported in the Study | Detailed Results Abstracted
RP vs. WW | All-Cause Mortality | PIVOT Wilt et al.25 | No reduction in all-cause mortality among men with PSA levels of 10 ng/mL or less who were treated with RP compared with WW after a median 10-year followup. All-cause mortality was reduced by 13.2% among men with PSA levels of more than 10 ng/mL who were treated with RP compared with WW. After median 10-year followup, there was a 31% relative reduction in all-cause mortality among men with intermediate-risk tumor risk who were treated with RP compared with WW. | Table F-1 in Appendix F
RP vs. WW | All-cause mortality | SPCG-4 Bill-Axelson et al.15,33,34 | No reduction in all-cause mortality among men with PSA levels <10 ng/mL or >10 ng/mL who were treated with RP compared with WW at 15-year followup. No reduction in all-cause mortality among men with Gleason score less than 7 or more than 7 who were treated with RP compared with WW at 15-year followup. There was a significant absolute between-group difference of 13.2% for all-cause mortality among men with low-risk tumor who were treated with RP than those in WW at 15-year followup. | Table F-1 in Appendix F
RP vs. WW | PCSM | PIVOT Wilt et al.25 | After a median 10-year followup, there was a significant reduction in PCSM among men with PSA >10 ng/mL who were treated with RP compared with WW. There was also a significant reduction in PCSM among men with high-risk tumor who were treated with RP compared with WW. | Table F-5 in Appendix F
RP vs. WW | PCSM | SPCG-4 Bill-Axelson et al.15,33,34 | No reduction in PCSM among men with PSA levels of less than 10 ng/mL or more than 10 ng/mL who were treated with RP compared with WW at 15-year followup. No reduction in PCSM among men with Gleason score less than 7 or more than 7 who were treated with RP compared with WW at 15-year followup. There was a nonsignificant absolute between-group difference of 4.2% for PCSM among men with low-risk tumor who were treated with RP than those in WW at 15-year followup. | Table F-5 in Appendix F
RP vs. WW | Distant metastases | SPCG-4 Bill-Axelson et al.15,33,34 | There was a significant absolute between-group difference of 11.4% for distant metastases among men with low-risk tumor who were treated with RP compared with WW at 15-year followup. | Table F-11 in Appendix F
EBRT vs. EBRT plus ADT | Overall survival | Jones et al.43 | Among men with intermediate-risk tumor, the 10-year overall survival was increased to 60% in the EBRT plus short-term ADT group compared with 54% in the EBRT alone group. Among men with low-risk tumor, the 10-year overall survival was increased to 67% in the EBRT plus short-term ADT group compared with 60% in the EBRT alone group. | Table F-3 in Appendix F
EBRT vs. EBRT plus ADT | PCSM | Jones et al.43 | The risk of PCSM was higher in the EBRT group than in the EBRT plus ADT. But no reduction in PCSM among men with low-risk tumor who were treated with EBRT alone compared with EBRT plus short-term ADT. | Table F-5 in Appendix F
EBRT vs. EBRT plus ADT | Biochemical failure | Jones et al.43 | The 10-year rate of biochemical failure was significantly reduced in all 3 risk subgroups (i.e., low-, intermediate, and high-risk) among men treated with in the EBRT plus short-term ADT group compared with EBRT alone. | Table F-7 in Appendix F
3D-CRT vs. 3D-CRT plus 6 months of both LHRH and antiandrogen vs. 3D-CRT plus 6 months of both LHRH and less than 6 months of antiandrogen | Biochemical failure | D'Amico et al.49 | After a median followup of 8.2 years, estimates of PSA recurrence were significantly lower in men with an increasing PSA level (RR 2.07; 95% CI, 1.4 to 3.1), a Gleason score of 8, 9, or 10 (RR 3.2; 95% CI, 1.7 to 6.0), and clinical category T2 disease (RR 1.9; 95% CI, 1.2 to 3.0). | Table F-7 in Appendix F

Abbreviations: 3D-CRT=Three-dimensional conformal radiation therapy; ADT=androgen-deprivation therapy; CI=confidence interval; EBRT=external beam radiation therapy; LHRH=luteinizing hormone-releasing hormone; PCSM=prostate cancer–specific mortality, PIVOT= Prostate Intervention Versus Observation Trial, PSA=prostate-specific antigen, RP=radical prostatectomy; RR=relative risk; SPCG-4= Scandinavian Prostate Cancer Group-4, WW=watchful waiting.

Table 31 Overview of nonrandomized comparative studies (16 studies): Key Question 4

Study | Number of Patients | Tumor Characteristics | Outcomes | Duration
Alemozaffar et al. 2014^68^ | RALRP: 132 patients vs. RRP: 468 patients | Risk level | QOL and satisfaction with cancer care | A minimum followup of 2 years
DeGroot et al. 2013^41^ | RP: 458 patients (cohort) vs. RP: 36 patients (cases) vs. EBRT: 518 patients (cohort) vs. EBRT: 78 patients (cases) | Tumor risk | PCSM | Median 51 months followup
Ferrer et al. 2013^91^ | RRP: 193 patients vs. 3D-CRT: 194 patients vs. BT: 317 patients | Tumor risk | Overall survival | Median 6.06-year followup
Hoffman et al. 2013^38^ | RP: 1,164 patients vs. EBRT: 491 patients | Tumor risk | All-cause mortality PCSM | 15-year followup
Wirth et al. 2013^74^ | RRP: 600 patients vs. LRP: 244 patients | PSA level Gleason score Tumor stage | Biochemical progression–free survival | Median followup of 6.6 years and 4.6 years, respectively.
Nanda et al. 2012^83^ | Low-risk: BT without neoadjunctive HT 3,517 patients vs. BT with neoadjunctive HT: 1,924 patients Intermediate-risk: BT without neoadjunctive HT 2,225 patients vs. BT with neoadjunctive HT 2,140 patients High-risk: BT without neoadjunctive HT: 353 patients vs. BT with neoadjunctive HT 1,007 patients | Tumor risk | AEs | Median followup for low-, intermediate-, and high-risk prostate cancer was 4.1 years, 4.4 years, and 4.6 years respectively.
Rosenberg et al. 2012^76^ | BT pus EBRT: 186 patients vs. BT plus ADT: 621 patients | PSA level Gleason score | PCSM | 4.4- and 4.8-year followup, respectively
Zelefsky et al. 2012^89^ | BT: 942 patients vs. BT plus IMRT: 524 patients | PSA level Gleason score Clinical T stage | Biochemical progression-free survival | Median followup 49 months (range 1–13 years)
Kibel et al. 2012^75^ | RP: 6,485 patients, 2,843 at site 1 and 3,642 at site 2 vs. 3D-CRT plus IMRT: 2,264 patients, 1,638 at site 1 and 626 at site 2 vs. BT: 1,680 patients, 1,330 at site 1 and 350 at site 2 | Tumor risk | Overall survival PCSM | 10-year followup
Abdollah et al. 2012^59^ | EBRT: 46,521 patients vs. Observation: 22,276 patients | Tumor risk | PCSM | 10-year followup
Rice et al. 2011^36^ | RP: 194 patients vs. EBRT: 252 patients vs. WW without secondary treatment: 214 patients vs. WW with secondary treatment: 110 patients | PSA level Tumor stage | Biochemical recurrence Overall mortality | Mean 6.8±4.0 years
Dosoretz et al. 2010^82^ | BT: 1,391 patients vs. BT plus ADT: 1,083 patients | PSA level Gleason score Tumor stage | All-cause mortality | Median followup 4.8 years
Magheli et al. 2010^56^ | RRP: 522 patients vs. LRP: 522 patients vs. RALRP: 522 patients | Gleason score | Biochemical recurrence | [underlined: Mean (SD) followup time] RRP: 2.5 (1.6) years LRP: 1.47 (0.7) years RALRP: 1.3 (0.6) years
Lu-Yao et al. 2008^78^ | ADT: 7,867 patients vs. Observation: 11,404 patients | Tumor grade | Overall survival PCSM | Median followup for overall survival was 81 months
Sumitomo et al. 2008^63^ | HIFU: 260 patients vs. HIFU + ADT: 270 patients | Tumor risk | Biochemical recurrence–free survival | 3-year followup
D'Amico et al. 2007^87^ | RRP: 660 patients vs. 3D-CRT: 288 patients | PSA level Biopsy Gleason score Tumor stage | PCSM | 7-year followup

Abbreviations: 3D-CRT=Three-dimensional conformal radiation therapy, ADT=androgen-deprivation therapy; BT=brachytherapy; EBRT=external beam radiation therapy; HIFU=high-intensity focused ultrasound; HT=hormone therapy, IMRT=intensity modulated radiation therapy, PCSM=prostate cancer–specific mortality, LRP=laparoscopic radical prostatectomy; PSA=prostate-specific antigen, RALRP=robotic-assisted laparoscopic radical prostatectomy; RP=radical prostatectomy; RRP=radical retropubic prostatectomy, WW=watchful waiting.

Table 32 Major findings reported by nonrandomized comparative studies for Key Question 4

Treatments Being Compared | Outcome | Evidence Base | Major Findings Reported in the Study | Detailed Results Abstracted
RALRP vs. RRP | Expanded Prostate Cancer Index scores (urinary incontinence, urinary obstruction, sexual, bowel, hormonal/vitality) | Alemozaffar et al.68 | Multivariate regression demonstrated no significant differences on any subscale scores when the analysis was limited to RALRP vs. RRP in the low-risk patients or between RALRP and RRP in the intermediate/high risk patients. | Table F-16 in Appendix F
RALRP vs. RRP | Satisfaction scale for cancer care (outcome satisfaction) | Alemozaffar et al.68 | Multivariate regression found no significant difference in patient satisfaction when the analysis was limited to RALRP vs. RRP in the low-risk patients or between RALRP and RRP in the intermediate-/high-risk patients. | Table F-16 in Appendix F
RALRP vs. RRP | Biochemical recurrence | Magheli et al.56 | When stratified by Gleason score, men with Gleason score of 6 or less had lower biochemical recurrence compared to men with Gleason score of 7 (HR 3.35; 95% CI, 1.27 to 8.83) or 8–10 (HR 9.98; 95% CI, 3.07 to 32.42). | Table F-8 in Appendix F
RRP vs. LRP | Biochemical recurrence | Magheli et al.56 | When stratified by Gleason score, men with Gleason score of 6 or less had lower biochemical recurrence compared to men with Gleason score of 7 (HR 3.35; 95% CI, 1.27 to 8.83) or 8–10 (HR 9.98; 95% CI, 3.07 to 32.42). | Table F-8 in Appendix F
LRP vs. RRP | BPFS | Wirth et al.74 | There was a significant between-group difference in biochemical progression–free survival when men were stratified by Gleason score, pathological stage, and PSA level. PSA level: HR 1.1; 95% CI, 1.10 to 1.16 Tumor stage: HR, 5.0; 95% CI, 3.44 to 7.16 Gleason score 7: HR 6.6; 95% CI, 4.3 to 10.0 Gleason score of 8 or more: HR 16.4; 9.0 to 29.8 | Table F-7 in Appendix F
3D-CRT vs. BT | Overall survival | Ferrer et al.91 | At median followup of 6.02 years, no statistically significant difference between the treatment groups when men with low-risk tumors were compared with intermediate-risk (HR 1.13; 95% CI, 0.54 to 2.36) | Table F-4 in Appendix F
RRP vs. BT | Overall survival | Ferrer et al.91 | At median followup of 6.02 years, no statistically significant difference between the treatment groups when men with low-risk tumors were compared with intermediate-risk (HR 1.13; 95% CI, 0.54 to 2.36) | Table F-4 in Appendix F
3D-CRT plus IMRT vs. BT | Overall survival | Kibel et al.75 | Comparisons were all to RP so no usable data. | Table F-4 in Appendix F
3D-CRT plus IMRT vs. BT | PCSM | Kibel et al.75 | There were no significant differences in PCSM within each prostate cancer risk group | Table F-6 in Appendix F
RP vs.BT | Overall survival | Kibel et al.75 | RP was associated with improved survival in all risk groups Low risk: BT vs. RP: (HR 1.7 [1.4 to 2.2]) Intermediate risk BT vs. RP (HR 1.5 [1.1 to 2.1]) High risk BT vs. RP (HR 3.1 [1.7 to 5.9]) | Table F-4 in Appendix F
RP vs.BT | PCSM | Kibel et al.75 | There were no significant differences in PCSM within each prostate cancer risk group | Table F-6 in Appendix F
RP vs. 3D-CRT plus IMRT | Overall survival | Kibel et al.75 | RP was associated with improved survival in all risk groups Low risk: EBRT vs. RP (HR 1.7, [1.3 to 2.1]) Intermediate risk EBRT vs. RP (HR 1.5 [1.2 to 1.9]) High risk EBRT vs. RP (HR 1.7 [1.3 to 2.3]) | Table F-4 in Appendix F
RP vs. 3D-CRT plus IMRT | PCSM | Kibel et al.75 | There were no significant differences in PCSM within each prostate cancer risk group | Table F-6 in Appendix F
RRP vs. 3D-CRT | Overall survival | Ferrer et al.91 | At median followup of 6.02 years, no statistically significant difference between the treatment groups when men with low-risk tumors were compared with intermediate-risk (HR 1.13; 95% CI, 0.54 to 2.36) | Table F-4 in Appendix F
RRP vs. 3D-CRT | PCSM | D'Amico et al.87 | After 7 years of followup, PCSM was more favorable for men with PSA level >20 ng/mL who underwent RRP compared with 3D-CRT (RR 0.48; 95% CI, 0.23 to 0.99) After 7 years of followup, PCSM was more favorable for men with Gleason score 7 who underwent RRP compared with 3D-CRT (RR 0.38; 95% CI, 0.17 to 0.86) After 7 years of followup, PCSM was more favorable for men with Gleason score 8–10 who underwent RRP compared with 3D-CRT (RR 0.44; 95% CI, 0.2 to 0.98) After 7 years of followup, PCSM was more favorable for men with stage T1c who underwent RRP compared with 3D-CRT (RR 0.23; 95% CI, 0.08 to 0.61) | Table F-6 in Appendix F
RP vs. EBRT | All-cause mortality | Hoffman et al.38 Rice et al.36 | Hoffman et al.38 After 15 years of followup, all-cause mortality was more favorable for men with high-risk tumor who underwent RP compared with EBRT (HR, 0.65; 95% CI, 0.48 to 0.87) Rice et al.36 PSA at diagnosis was not a significant predictor of overall survival. Clinical T stage was not a significant predictor of overall survival. | Table F-2 in Appendix F
RP vs. EBRT | PCSM | Hoffman et al.38 and DeGroot et al.41 | DeGroot et al.41 At median followup of 51 months, there was no evidence of worse PCSM among men with low-risk or intermediate-risk tumor who underwent EBRT compared with RP (HR 1.57; 95% CI, 0.95 to 2.61). Hoffman et al.38 After 15 years of followup, PCSM was more favorable for the men with high-risk tumor who underwent RP than for the men who received EBRT (HR, 0.36; 95% CI, 0.20 to 0.64). | Table F-6 in Appendix F
RP vs. EBRT | Biochemical recurrence | Rice et al.36 | PSA significantly predicted biochemical recurrence with higher PSA scores experiencing more recurrence. Clinical T stage was not a significant predictor of biochemical recurrence. | Table F-2 in Appendix F Table F-7 in Appendix F
RALRP vs. LRP | Biochemical recurrence | Magheli et al. 2011^56^ | When stratified by Gleason score, men with Gleason score of 6 or less had lower biochemical recurrence than did men with Gleason score of 7 (HR 3.35; 95% CI, 1.27 to 8.83) or 8–10 (HR 9.98; 95% CI, 3.07 to 32.42). | Table F-8 in Appendix F
EBRT vs. observation | Overall mortality | Rice et al.36 | PSA at diagnosis was not a significant predictor of overall survival. Clinical T stage was not a significant predictor of overall survival. | Table F-2 in Appendix F
EBRT vs. Observation | PCSM | Abdollah et al.59 | For patients in the high-risk group, 10-year PCSM was 8.8% in the radiotherapy group vs. 14.4% in the observation group (HR 0.59; 95% CI, 0.50 to 0.68) in favor of EBRT. For patients in the low to high-risk group, there was no between-group difference in the same outcome. | Table F-6 in Appendix F
EBRT vs. Observation | Biochemical recurrence | Rice et al.36 | PSA at diagnosis was not a significant predictor of overall survival. Clinical T stage was not a significant predictor of overall survival. PSA significantly predicted biochemical recurrence with higher PSA scores experiencing more recurrence. Clinical T stage was not a significant predictor of biochemical recurrence. | Table F-7 in Appendix F
BT vs. BT Plus ADT | All-cause mortality | Dosoretz et al.82 | Study authors only reported no significant difference in all-cause mortality between the interventions when data were stratified by PSA level, biopsy Gleason sore, and clinical T stage in either study group. | Table F-2 in Appendix F
BT vs.BT plus HT | AEs | Nanda et al.83 | Neoadjunctive HT use was associated with a significantly increased risk of all-cause mortality in men with low-risk prostate cancer (adjusted HR 1.27, 95% CI 1.07 to 1.51, p<0.01) but not in men with intermediate-risk prostate cancer (adjusted HR 1.13, 95% CI 0.96 to 1.35, p=0.15) or high-risk prostate cancer (adjusted HR 0.86, 95% CI 0.66 to 1.13, p0.28) using multivariate regression with propensity score. Among low-risk patients, adjuvant HT was associated with a significantly increased risk of all-cause mortality in men with at least 1 CAD risk factor (adjusted HR 1.36; 95% CI, 1.07 to 1.74, p=0.01) but not in patients with no CAD risk factors (adjusted HR 1.19; 95% CI 0.95 to 1.51, p=0.13). The authors reported all-cause mortality as a possible adverse event of HT use. | Table F-16 in Appendix F
BT plus EBRT vs. BT plus ADT | PCSM | Rosenberg et al.76 | At 5 years, men with a Gleason score of 4+3 (adjusted HR 8.88; 95% CI, 1.10 to 72.04) and elevated PSA level (adjusted HR 8.03; 95% CI, 2.38 to 28.80) who received BT plus EBRT had an increased risk of PCSM compared with those treated with EBRT plus ADT. | Table F-6 in Appendix F
BT vs. BT plus IMRT | BPFS | Zelefsky et al.89 | In a multivariate analysis, PSA level and Gleason score were significantly associated with BPFS, while clinical T stage was not significantly associated with BPFS. | Table F-7 in Appendix F
ADT vs. observation | All-cause mortality | Lu-Yao et al.78 | The all-cause mortality rate among men with moderately-differentiated cancer was higher in the ADT group than in the observation group (adjusted HR 1.15; 95% CI, 1.10 to 1.21). | Table F-2 in Appendix F
ADT vs. Observation | PCSM | Lu-Yao et al.78 | The PCSM rate among men with moderately-differentiated cancer was higher in the ADT group than in the observation group (adjusted HR 1.83; 95% CI, 1.58 to 2.12). | Table F-6 in Appendix F
HIFU vs. HIFU plus ADT | BPFS | Sumitomo et al.63 | PSA level and T stage were significantly associated with BPFS in both groups, while Gleason score was not significantly associated. Patients with HIFU alone had significantly lower BPFS compared to HIFU + ADT only in the intermediate- and high-risk groups: 3-year BPFS among men with low-risk prostate cancer (86.1% vs. 89.7%, p=0.60); intermediate-risk prostate cancer (44.9% vs. 79.3%, p=0.01); high-risk prostate cancer (32.6% vs. 66.8%, p=0.03) | Table F-7 in Appendix F
RP vs. observation | Overall mortality Biochemical recurrence | Rice et al.36 | PSA at diagnosis was not a significant predictor of overall survival. Clinical T stage was not a significant predictor of overall survival. PSA significantly predicted biochemical recurrence with higher PSA scores experiencing more recurrence. Clinical T stage was not a significant predictor of biochemical recurrence. | Table F-2 in Appendix F Table F-7 in Appendix F

Abbreviations: 3D-CRT=Three-dimensional conformal radiation therapy; ADT=androgen-deprivation therapy; BT=brachytherapy; EBRT=external beam radiation therapy; HIFU=high-intensity focused ultrasound; IMRT=intensity-modulated radiation therapy; LRP=laparoscopic radical prostatectomy; PCSM=prostate cancer–specific mortality; RALRP=robotic-assisted laparoscopic radical prostatectomy; RP=radical prostatectomy; RRP=radical retropubic prostatectomy.

Table 33 Key Question 4: Strength-of-evidence grades for randomized controlled trials across primary treatment categories

Comparison | Outcome | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Grade
RP vs. WW25 | All-cause mortality among patients with PSA levels >10 ng/mL (n=138) at 10-year followup | Medium | Consistency unknown (single study) | Direct | Precise HR 0.67 (95% CI, 0.48 to 0.94). Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. WW25 | All-cause mortality among patients with PSA levels ≤10 ng/mL (n=211); low-risk (n=116), intermediate-risk (n=129), or high-risk (n=91) prostate cancer; Gleason score <7 (n=238) or ≥7 (n=97) at 10-year followup | Medium | Consistency unknown (single study) | Direct | Imprecise Effect size was not statistically significant for all subgroups | No significant difference between the interventions | Insufficient for all patient subgroups
RP vs. WW25 | PCSM among patients with PSA levels ≤10 ng/mL (n=29) or >10 ng/mL (n=23); low-risk (n=10), intermediate-risk (n=19), high-risk (n=21) prostate cancer; Gleason score <7 or ≥7 at 10-year followup | Medium | Consistency unknown (single study) | Direct | Imprecise Effect size was not statistically significant for all subgroups. | No significant difference between the interventions | Insufficient for all patient subgroups
RP vs. WW33 | Overall mortality among patients with low-risk prostate cancer at 15-year followup (study did not report number of patients in this subgroup) | Medium | Consistency unknown (single study) | Direct | Precise RR (95% CI 0.62, 0.42 to 0.92). Effect size was statistically significant. | RP | Insufficient for patient subgroup^*^
RP vs. WW33 | PCSM among patients with low-risk prostate cancer at 15-year followup (study did not report number of patients in this subgroup) | Medium | Consistency unknown (single study) | Direct | Imprecise RR 0.53 (95% CI, 0.24 to 1.14). Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
RP vs. WW33 | Progression to distant metastases in patients with low risk disease at 15-year followup (study did not report number of patients in this subgroup) | Medium | Consistency unknown (single study) | Direct | Precise RR 0.43 (95% CI, 0.23 to 0.79). Effect size was statistically significant. | RP | Insufficient for patient subgroup

* SOE grading reduced by one level based on subgroup analysis (see methods section for further details).

Abbreviations: CI=Confidence interval; HR=hazard ratio; PCSM=prostate cancer–specific mortality; PSA=prostate-specific antigen; RP=radical prostatectomy; RR=relative risk; SOE=strength of evidence; WW=watchful waiting.

Table 34 Key Question 4: Strength-of-evidence grades for randomized controlled trials within primary treatment categories

Comparison | Outcome | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Grade
EBRT vs. EBRT plus short-term ADT therapy43 | Overall survival among patients with intermediate-risk (n=1,068) prostate cancer at median followup of 9.1 years No treatment by risk category association was found in the low- or high-risk groups. | Medium | Consistency unknown (single study) | Direct | Precise Intermediate risk HR 1.23 (95% CI, 1.02 to 1.49) Effect size was statistically significant. | EBRT plus ADT | Insufficient for patient subgroup
EBRT vs. EBRT plus short-term ADT therapy43 | PCSM among patients with intermediate risk (n=1,068) prostate cancer at 10-year followup No treatment by risk category association was found in the low- or high-risk groups | Medium | Consistency unknown (single study) | Direct | Precise Intermediate risk HR 2.49 (95% CI, 1.50 to 4.11) Effect size was statistically significant. | EBRT plus ADT | Insufficient for patient subgroup

Abbreviations: ADT=Androgen-deprivation therapy; CI=confidence interval; EBRT=external beam radiation therapy; HR=hazard ratio; PCSM=prostate cancer–specific mortality; SOE=strength of evidence.

Table 35 Key Question 4: Strength-of-evidence grades for nonrandomized comparative studies

Comparison | Outcome | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Grade
RRP vs. 3D-CRT vs. BT91 | Overall survival among men with low risk (n=415) vs. men with intermediate risk (n=28) at median followup of 6.06 years | High | Consistency unknown (single study) | Direct | Imprecise HR 1.13 (95% CI, 0.54 to 2.36). Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
RRP vs. 3D-CRT87 | PCSM among men with PSA >20 (n=77) | High | Consistency unknown (single study) | Direct | Precise RR 0.48, 95% CI, 0.23 to 0.99. Effect size was statistically significant. | RRP | Insufficient for patient subgroup
RRP vs. 3D-CRT87 | PCSM among men with Gleason score 7 (n=419) | High | Consistency unknown (single study) | Direct | Precise RR 0.38, 95% CI, 0.17 to 0.86. Effect size was statistically significant. | RRP | Insufficient for patient subgroup
RRP vs. 3D-CRT87 | PCSM among men with Gleason score 8–10 (n=114) | High | Consistency unknown (single study) | Direct | Precise RR 0.44, 95% CI, 0.2 to 0.98). Effect size was statistically significant. | RRP | Insufficient for patient subgroup
RRP vs. 3D-CRT87 | PCSM among men with T1c (n=567) | High | Consistency unknown (single study) | Direct | Precise RR 0.23, 95% CI, 0.08 to 0.61. Effect size was statistically significant. | RRP | Insufficient for patient subgroup
RRP vs. 3D-CRT87 | PCSM among men with PSA ≤4 (n=162), >4–10 (n=519), >10–12 (n=180), >20 (n=87), biopsy Gleason score ≤6 (n=415), T2a (n=219), T2b (n=107), T2c (n=43), and T3a or T3b (n=12) | High | Consistency unknown (single study) | Direct | Imprecise (p-values were not statistically significant for all sub groups) | No significant difference between the interventions | Insufficient for patient subgroup
BT vs. BT plus ADT82 | All-cause mortality among patients stratified by PSA level (≤4 [n=247], 4–10 [n=1,783], 10–20 [n=382], >20 [n=69]), biopsy Gleason score (≤6 [n=1,047], 7 [n=181], 8–10 [40], and clinical T classification (T1 [n=787], T2 [n=475], (T3 [n=6]) at a median followup of 4.8 years | High | Consistency unknown (single study) | Direct | Imprecise (p-values were not statistically significant for all sub groups) | No significant difference between the interventions | Insufficient for all patient subgroups
BT plus EBRT vs. BT plus ADT76 | PCSM among patients with a Gleason score 4+3 (n=180) at median followup of 4.4 years and 4.8 years, respectively | High | Consistency unknown (single study) | Direct | Precise HR 8.88 (95% CI, 1.10 to 72.04) Effect size was statistically significant. | BT plus EBRT | Insufficient for patient subgroup
BT plus EBRT vs. BT plus ADT76 | PCSM among patients with elevated PSA levels (n=410) at median followup of 4.4 years and 4.8 years, respectively | High | Consistency unknown (single study) | Direct | Precise HR 8.03 (95% CI, 2.38 to 28.80) Effect size was statistically significant. | BT plus EBRT | Insufficient for patient subgroup
RP vs. EBRT vs. BT75 | Overall survival among patients with low-risk prostate cancer (n=685) at 10-year followup | High | Consistency unknown (single study) | Direct | RP vs. EBRT Precise HR 1.7 (95% CI, 1.3 to 2.1) Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. EBRT vs. BT75 | Overall survival among patients with low-risk prostate cancer (n=685) at 10-year followup | High | Consistency unknown (single study) | Direct | RP vs. BT Precise HR 1.7 (95% CI, 1.4 to 2.2) Effect size was statistically significant | RP | Insufficient for patient subgroup
RP vs. EBRT vs. BT75 | Overall survival among patients with intermediate-risk prostate cancer (n=1,068) at 10-year followup | High | Consistency unknown (single study) | Direct | RP vs. EBRT Precise HR 1.5 (95% CI, 1.2 to 1.9) Effect size was statistically significant | RP | Insufficient for patient subgroup
RP vs. EBRT vs. BT75 | Overall survival among patients with intermediate-risk prostate cancer (n=1,068) at 10-year followup | High | Consistency unknown (single study) | Direct | RP vs. BT Precise HR 1.5 (95% CI, 1.1 to 2.1) Effect size was statistically significant | RP | Insufficient for patient subgroup
RP vs. EBRT vs. BT75 | Overall survival among patients with high-risk prostate cancer (n=226) at 10-year followup | High | Consistency unknown (single study) | Direct | RP vs EBRT Precise HR 1.7 (95% CI, 1.3 to 2.3) Effect size was statistically significant | RP | Insufficient for patient subgroup
RP vs. EBRT vs. BT75 | Overall survival among patients with high-risk prostate cancer (n=226) at 10-year followup | High | Consistency unknown (single study) | Direct | RP vs. BT Precise HR 3.1 (95% CI, 1.7 to 5.9) Effect size was statistically significant | RP | Insufficient for patient subgroup
RP vs. EBRT vs. BT75 | PCSM among patients with low-risk prostate cancer (n=685) at 10-year followup | High | Consistency unknown (single study) | Direct | RP vs. EBRT Imprecise HR 1.8 (95% CI, 0.5 to 6.2) Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
RP vs. EBRT vs. BT75 | PCSM among patients with low-risk prostate cancer (n=685) at 10-year followup | High | Consistency unknown (single study) | Direct | RP vs. BT Imprecise HR 2.3 (95% CI, 0.8 to 6.9) Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
RP vs. EBRT vs. BT75 | PCSM among patients with intermediate-risk prostate cancer (n=1,068) at 10-year followup | High | Consistency unknown (single study) | Direct | RP vs. EBRT Imprecise HR 1.8 (95% CI, 0.8 to 3.8) Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
RP vs. EBRT vs. BT75 | PCSM among patients with intermediate-risk prostate cancer (n=1,068) at 10-year followup | High | Consistency unknown (single study) | Direct | RP vs. BT Imprecise HR 0.6 (95% CI, 0.1 to 2.7) Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
RP vs. EBRT vs. BT75 | PCSM among patients with high-risk prostate cancer (n=226) at 10-year followup | High | Consistency unknown (single study) | Direct | RP vs. EBRT Imprecise HR 1.3 (95% CI, 0.8 to 2.1) Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
RP vs. EBRT vs. BT75 | PCSM among patients with high-risk prostate cancer (n=226) at 10-year followup | High | Consistency unknown (single study) | Direct | RP vs. BT Imprecise HR 1.6 (95% CI, 0.4 to 6.6) Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
Observation vs. EBRT59 | PCSM among men with low- to intermediate-risk prostate cancer at 10-year followup (study did not report number of patients in this subgroup) | High | Consistency unknown (single study) | Direct | Imprecise HR 0.91 (0.80 to 1.04) Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for all patient subgroups
Observation vs. EBRT59 | PCSM among men with high risk prostate cancer at 10-year followup (study did not report number of patients in this subgroup) | High | Consistency unknown (single study) | Direct | Precise HR 0.59 (0.50 to 0.60) Effect size was statistically significant. | EBRT | Insufficient for patient subgroup
Observation vs. ADT78 | All-cause mortality rate per 100 among men with poorly-differentiated prostate cancer (n=4,303) at 81-month followup | Medium | Consistency unknown (single study) | Direct | Imprecise HR 1.04 (95% CI, 0.97 to 1.13) Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
Observation vs. ADT78 | All-cause mortality rate per 100 among men with moderately-differentiated prostate cancer (n=14,660) at 81-month followup | Medium | Consistency unknown (single study) | Direct | Precise HR 1.15 (95% CI, 1.10 to 1.21) Effect size was statistically significant. | Observation | Insufficient for patient subgroup
Observation vs. ADT78 | PCSM rate per 100 among men with poorly-differentiated prostate cancer (n=4,303) at 81-month followup | Medium | Consistency unknown (single study) | Direct | Imprecise HR 1.12 (95% CI, 0.96 to 1.29) Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
Observation vs. ADT78 | PCSM rate per 100 among men with moderately-differentiated prostate cancer (n=14,660) at 81-month followup | Medium | Consistency unknown (single study) | Direct | Imprecise HR 1.83 (95% CI, 1.58 to 2.12) Effect size was statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
RP vs. EBRT (plus ADT)38 | All-cause mortality among men with high-risk, diagnostic PSA levels >10 ng/mL or Gleason score ≥8^*^ (n=437) at 15-year followup | High | Consistency unknown (single study) | Direct | Precise HR 0.65 (95% CI, 0.48 to 0.87). Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. EBRT (plus ADT)38 | All-cause mortality among men with low-risk, diagnostic PSA levels <10 ng/mL or Gleason score ≤6^*^ (n=753) at 15-year followup | High | Consistency unknown (single study) | Direct | Precise HR 0.78 (95% CI, 0.63 to 0.96). Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. EBRT (plus ADT)38 | PCSM among men with high-risk, diagnostic PSA levels >10 ng/mL or Gleason ≥8^*^ (n=437) at 15-year followup | High | Consistency unknown (single study) | Direct | Precise HR 0.78 (95% CI, 0.63 to 0.96). Effect size was statistically significant. | RP | Insufficient for patient subgroup
RP vs. EBRT (plus ADT)38 | PCSM among men with low-risk, diagnostic PSA levels <10 ng/mL or Gleason score ≤6^*^ (n=753) at 15-year followup | High | Consistency unknown (single study) | Direct | Imprecise HR 0.66 (95% CI, 0.35 to 1.25). Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
RP vs. EBRT41 | PCSM for low-risk group (PSA levels ≤10, Gleason score ≤6 and T category ≤T2a) (n=386; 371 cohort and 15 cases) | High | Consistency unknown (single study) | Direct | Imprecise HR 0.87 (95% CI 0.28 to 2.76). Effect size was not statistically significant. | No significant difference between the interventions | Insufficient for patient subgroup
RP vs. EBRT vs. WW with and without secondary treatment36 | Overall mortality | High | Consistency unknown (single study) | Direct | Imprecise for PSA and clinical T stage | No significant difference | Insufficient for patient subgroup
RALRP vs. RRP68 | QOL | High | Consistency unknown (single study) | Direct | Imprecise | No significant difference between the interventions by risk level | Insufficient for patient subgroup

*Only patients with Gleason score of 8 or more received ADT along with EBRT.

Abbreviations: 3D-CRT=Three-dimensional conformal radiotherapy; ADT=androgen-deprivation therapy; BT=brachytherapy; CI=confidence interval; EBRT=external beam radiation therapy; HR=hazard ratio; IMRT=intensity modulated radiotherapy; PCSM=prostate cancer–specific mortality; PSA=prostate-specific antigen; QOL=quality of life; RALRP=robotic-assisted laparoscopic radical prostatectomy; RP=radical prostatectomy; RR=relative risk; RRP=radical retropubic prostatectomy; SOE=strength of evidence.

### Key Points

RCTs that performed subgroup analyses based on tumor characteristics reported the following. In all cases, the strength of evidence was insufficient to allow conclusions.

- PSA levels. PIVOT found no reduction in all-cause mortality among men with PSA levels of ≤10 ng/mL treated with RP compared with WW. All-cause mortality (but not PCSM) was reduced by 13.2% among men with PSA levels of >10 ng/mL who were treated with RP compared with WW.
- PSA levels. The SPCG-4 trial found no reduction in all-cause mortality among men with PSA levels of <10 ng/mL or >10 ng/mL treated with RP compared with WW at 15-year followup.
- Gleason score. SPCG-4 found no reduction in all-cause mortality among men with Gleason score <7 or >7 treated with RP compared with WW at 15-year followup.
- Risk level. PIVOT found a 31% relative reduction in all-cause mortality among men with intermediate tumor risk treated with RP compared with WW. Furthermore, there was a significant reduction in PCSM among men with PSA >10 ng/mL and men with high-risk tumor who were treated with RP compared with WW.
- Risk level. SPCG-4 found a significant absolute between-group difference of 13.2% for all-cause mortality and 11.4% for distant metastases among men with low-risk tumor who were treated with RP than those in WW at 15-year followup.
- Risk level. Among men with intermediate-risk tumors, overall survival was increased to 60% in the EBRT plus ADT group compared with 54% in the EBRT alone group. Among men with low-risk tumors, overall survival was increased to 67% in the EBRT plus ADT group compared with 60% in the EBRT alone group. The study found no reduction in PCSM among men with low-risk tumor who were treated with EBRT alone compared with EBRT plus ADT.

### Detailed Synthesis

#### Randomized Controlled Trials

All abstracted data for the outcome measures that address this KQ appear in Appendix F. Table 30 summarizes major findings reported by the RCTs and is intended to provide a roadmap to the abstracted data, including the key statistics, for each comparison and reported outcome. The strength-of-evidence grades for studies that address this Key Question are provided in Table 33 and Table 34.

#### Nonrandomized Comparative Studies

All abstracted data for the outcome measures that address this KQ appear in Appendix F. Table 32 summarizes major findings reported by the non-RCTs and is intended to provide a roadmap to the abstracted data, including the key statistics, for each comparison and reported outcome. The strength-of-evidence grades for nonrandomized comparative studies that address this Key Questions are provided in Table 35.