# References

1 American Cancer Society (ACS). Cancer facts & figures 2012. Atlanta (GA). American Cancer Society (ACS). 2012. 65 p. Also available: http://www.cancer.org/acs/groups/content/@epidemiologysurveilance/documents/document/acspc-031941.pdf.
2 American Urological Association Education and Research, Inc. Prostate-specific antigen best practice statement: 2009 update. Linthicum (MD). American Urological Association Education and Research, Inc. 2009. 82 p. Also available: http://www.auanet.org/content/guidelines-and-qualitycare/clinical-guidelines/main-reports/psa09.pdf.
3 Ganz PA, Barry JM, Burke W, et al. National Institutes of Health State-of-the-Science Conference statement: role of active surveillance in the management of men with localized prostate cancer. NIH Consens State Sci Statements. Dec. 5-7. 2011;28(1):1-27. [pmid: 23392076].
4 Thompson I, Thrasher JB, Aug G, et al. Guideline for the management of clinically localized prostate cancer: 2007 update. American Urological Association Education and Research, Inc. 2007. Also available: http://auanet.org/guidelines.
5 Thompson IM, Goodman PJ, Tangen CM, et al. The influence of finasteride on the development of prostate cancer. N Engl J Med. Jul. 17. 2003;349(3):215-24. [pmid: 12824459].
6 Screening for prostate cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. Jul. 17. 2012;157(2):120-34. [pmid: 22801674].
7 Brett AS, Ablin RJ. Prostate-cancer screening--what the U.S. Preventive Services Task Force left out. N Engl J Med. Nov. 24. 2011;365(21):1949-51. [pmid: 22029759].
8 Fowler FJ Jr, Barry MJ, Walker-Corkery B, et al. The impact of a suspicious prostate biopsy on patients' psychological, socio-behavioral, and medical care outcomes. J Gen Intern Med. Jul. 2006;21(7):715-21. [pmid: 16808772].
9 McNaughton-Collins M, Fowler FJ Jr, Caubet JF, et al. Psychological effects of a suspicious prostate cancer screening test followed by a benign biopsy result. Am J Med. Nov. 15. 2004;117(10):719-25. [pmid: 15541320].
10 Ransohoff DF, McNaughton Collins M, et al. Why is prostate cancer screening so common when the evidence is so uncertain? A system without negative feedback. Am J Med. Dec. 1. 2002;113(8):663-7. [pmid: 12505117].
11 Eckersberger E, Finkelstein J, Sadri H, et al. Screening for prostate cancer: a review of the ERSPC and PLCO trials. Rev Urol. Summer. 2009;11(3):127-33. [pmid: 19918338].
12 Hugosson J, Carlsson S, Aus G, et al. Mortality results from the Goteborg randomised population-based prostate-cancer screening trial. Lancet Oncol. Aug. 2010;11(8):725-32. [pmid: 20598634].
13 Humphrey PA. Gleason grading and prognostic factors in carcinoma of the prostate. Mod Pathol. Mar. 2004;17(3):292-306. [pmid: 14976540].
14 What's new in prostate cancer research?. American Cancer Society. 2012. Sep. 04. Available: http://www.cancer.org/cancer/prostatecancer/detailedguide/prostate-cancer-new-research. 2012 Dec 13.
15 Bill-Axelson A, Holmberg L, Filen F, et al. Radical prostatectomy versus watchful waiting in localized prostate cancer: the Scandinavian Prostate Cancer Group-4 randomized trial. J Natl Cancer Inst. Aug. 20. 2008;100(16):1144-54. [pmid: 18695132].
16 Reese AC, Sadetsky N, Carroll PR, Cooperberg MR. Inaccuracies in assignment of clinical stage for localized prostate cancer. Cancer. Jan. 15. 2011;117(2):283-9. Also available: http://dx.doi.org/10.1002/cncr.25596. [pmid: 21210472].
17 Meurs P, Galvin R, Fanning DM, et al. Prognostic value of the CAPRA clinical prediction rule: a systematic review and meta-analysis. BJU Int. Mar. 2013;111(3):427-36. Epub 2012 Aug 9. [pmid: 22882877].
18 Halverson S, Schipper M, Blas K, et al. The Cancer of the Prostate Risk Assessment (CAPRA) in patients treated with external beam radiation therapy: evaluation and optimization in patients at higher risk of relapse. Radiother Oncol. Dec. 2011;101(3):513-20. [pmid: 21703711].
19 Cooperberg MR, Simko JP, Cowan JE, et al. Validation of a cell-cycle progression gene panel to improve risk stratification in a contemporary prostatectomy cohort. J Clin Oncol. Apr. 10. 2013;31(11):1428-34. [pmid: 23460710].
20 Punnen S, Freedland SJ, Presti JC Jr, et al. Multi-institutional validation of the CAPRA-S score to predict disease recurrence and mortality after radical prostatectomy. Eur Urol. Jun. 2014;65(6):1171-7. Epub 2013 Apr 8. [pmid: 23587869].
21 National Comprehensive Cancer Network (NCCN). NCCN clinical practice guidelines in oncology: prostate cancer. V4.2013. [slide set]. Fort Washington (PA). National Comprehensive Cancer Network (NCCN). 2013. Jul. 26. 79 p. Also available: http://www.nccn.org/professionals/physician_gls/pdf/prostate.pdf.
22 Wilt TJ, Shamliyan T, Taylor B, et al. Comparative effectiveness of therapies for clinically localized prostate cancer. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2008. Feb. (Comparative Effectiveness Reviews; no.13). Also available: http://www.ncbi.nlm.nih.gov/books/NBK43147/. [pmid: 20704036].
23 Schneider Chafen J, Newberry S, Maglione M, et al. Comparative effectiveness of therapies for clinically localized prostate cancer Surveillance report. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2012. May. 50 p.
24 Wilt TJ, Brawer MK, Barry MJ, et al. The Prostate cancer Intervention Versus Observation Trial:VA/NCI/AHRQ Cooperative Studies Program #407 (PIVOT): design and baseline results of a randomized controlled trial comparing radical prostatectomy to watchful waiting for men with clinically localized prostate cancer. Contemp Clin Trials. Jan. 2009;30(1):81-7. [pmid: 18783735].
25 Wilt TJ, Brawer MK, Jones KM, et al. Radical prostatectomy versus observation for localized prostate cancer. N Engl J Med. Jul. 19. 2012;367(3):203-13. [pmid: 22808955].
26 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2011. Aug. 171 p. Also available: Chapters available at http://www.effectivehealthcare.ahrq.gov.
27 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. Sep. 2000;53(9):964-72. [pmid: 11004423].
28 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 2002;31(1):115-23. [pmid: 11914306].
29 Dawson B, Trapp RG. Basic & clinical biostatistics (LANGE Basic Science). McGraw-Hill/Appleton & Lange. 2004.
30 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the risk of bias of individual studies in systematic reviews of health care interventions. [AHRQ Publication No. 12-EGC047-EF]. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2012. Mar. 33 p. (Methods guide for comparative effectiveness reviews). Also available: http://www.effectivehealthcare.ahrq.gov.
31 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
32 Atkins D, Chang S, Gartlehner G, et al. Assessing applicability when comparing medical interventions: Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. Epub 2011 Apr 3. [pmid: 21463926].
33 Bill-Axelson A, Holmberg L, Ruutu M, et al. Radical prostatectomy versus watchful waiting in early prostate cancer. N Engl J Med. May. 5. 2011;364(18):1708-17. [pmid: 21542742].
34 Holmberg L, Bill-Axelson A, Steineck G, et al. Results from the Scandinavian Prostate Cancer Group Trial Number 4: a randomized controlled trial of radical prostatectomy versus watchful waiting. J. Natl. Cancer Inst. Monographs. Dec. 2012;2012(45):230-3. [pmid: 23271778].
35 D'Amico AV, Chen MH, Renshaw AA, et al. Androgen suppression and radiation vs radiation alone for prostate cancer: a randomized trial. JAMA. Jan. 23. 2008;299(3):289-95. [pmid: 18212313].
36 Rice KR, Colombo ML, Wingate J, Chen Y, Cullen J, McLeod DG, Brassell SA. Low risk prostate cancer in men >/= 70 years old: To treat or not to treat. Urol Oncol. Aug. 2013;31(6):755-60. Epub 2011 Aug 26. [pmid: 21872499].
37 Mukherjee S, Reddy CA, Ciezki JP, et al. Risk of developing myelodysplastic syndromes in prostate cancer patients definitively treated with radiation. J Natl Cancer Inst. Mar. 2014;106(3):djt462. Epub 2014 Feb 27. [pmid: 24577815].
38 Hoffman RM, Koyama T, Fan KH, et al. Mortality after radical prostatectomy or external beam radiotherapy for localized prostate cancer. J Natl Cancer Inst. May. 15. 2013;105(10):711-8. [pmid: 23615689].
39 Cooperberg MR, Vickers AJ, Broering JM, et al. Comparative risk-adjusted mortality outcomes after primary surgery, radiotherapy, or androgen-deprivation therapy for localized prostate cancer. Cancer. Nov. 15. 2010;116(22):5226-34. [pmid: 20690197].
40 Nepple KG, Stephenson AJ, Kallogjeri D, et al. Mortality after prostate cancer treatment with radical prostatectomy, external-beam radiation therapy, or brachytherapy in men without comorbidity. Eur Urol. Sep. 2013;64(3):372-8. Epub 2013 Mar 13. [pmid: 23506834].
41 Degroot JM, Brundage MD, Lam M, et al. Prostate cancer-specific survival differences in patients treated by radical prostatectomy versus curative radiotherapy. Can Urol Assoc J. May. 2013;7(5-6):E299-305. [pmid: 23766831].
42 Albertsen PC, Hanley JA, Penson DF, et al. 13-year outcomes following treatment for clinically localized prostate cancer in a population based cohort. J Urol. Mar. 2007;177(3):932-6. [pmid: 17296379].
43 Jones CU, Hunt D, McGowan DG, et al. Radiotherapy and short-term androgen deprivation for localized prostate cancer. N Engl J Med. Jul. 14. 2011;365(2):107-18. [pmid: 21751904].
44 Giberti C, Chiono L, Gallo F, et al. Radical retropubic prostatectomy versus brachytherapy for low-risk prostatic cancer: a prospective study. World J Urol. Oct. 2009;27(5):607-12. [pmid: 19455340].
45 Porpiglia F, Morra I, Lucci Chiarissi M, et al. Randomised controlled trial comparing laparoscopic and robot-assisted radical prostatectomy. Eur Urol. Jul. 20. 2012;63(4):606-14. [pmid: 22840353].
46 Martis G, Diana M, Ombres M, et al. Retropubic versus perineal radical prostatectomy in early prostate cancer: eight-year experience. J Surg Oncol. May. 1. 2007;95(6):513-8. [pmid: 17226809].
47 Donnelly BJ, Saliken JC, Brasher PM, et al. A randomized trial of external beam radiotherapy versus cryoablation in patients with localized prostate cancer. Cancer. Jan. 15. 2010;116(2):323-30. [pmid: 19937954].
48 Bill-Axelson A, Garmo H, Holmberg L, et al. Long-term distress after radical prostatectomy versus watchful waiting in prostate cancer: a longitudinal study from the Scandinavian Prostate Cancer Group-4 randomized clinical trial. Eur Urol. Dec. 2013;64(6):920-8. Epub 2013 Feb 26. [pmid: 23465517].
49 D'Amico AV, Chen MH, Renshaw AA, et al. Risk of prostate cancer recurrence in men treated with radiation alone or in conjunction with combined or less than combined androgen suppression therapy. J Clin Oncol. Jun. 20. 2008;26(18):2979-83. [pmid: 18565884].
50 Latchamsetty KC, Borden LS Jr, Porter CR, et al. Experience improves staging accuracy of endorectal magnetic resonance imaging in prostate cancer: what is the learning curve. Can J Urol. Feb. 2007;14(1):3429-34. [pmid: 17324322].
51 Johansson E, Steineck G, Holmberg L, et al. Long-term quality-of-life outcomes after radical prostatectomy or watchful waiting: the Scandinavian Prostate Cancer Group-4 randomised trial. Lancet Oncol. Sep. 2011;12(9):891-9. [pmid: 21821474].
52 Robinson JW, Donnelly BJ, Siever JE, Saliken JC, Ernst SD, Rewcastle JC, Trpkov K, Lau H, Scott C, Thomas B. A randomized trial of external beam radiotherapy versus cryoablation in patients with localized prostate cancer: quality of life outcomes. Cancer. Oct. 15. 2009;115(20):4695-704. [pmid: 19691092].
53 Nguyen PL, Chen MH, Renshaw AA, et al. Survival following radiation and androgen suppression therapy for prostate cancer in healthy older men: implications for screening recommendations. Int J Radiat Oncol Biol Phys. Feb. 1. 2010;76(2):337-41. [pmid: 19395186].
54 Schroeck FR, Sun L, Freedland SJ, et al. Comparison of prostate-specific antigen recurrence-free survival in a contemporary cohort of patients undergoing either radical retropubic or robot-assisted laparoscopic radical prostatectomy. BJU Int. Jul. 2008;102(1):28-32. [pmid: 18384634].
55 Resnick MJ, Koyama T, Fan KH, Albertsen PC, Goodman M, Hamilton AS, Hoffman RM, Potosky AL, Stanford JL, Stroup AM, Van Horn RL, Penson DF. Long-term functional outcomes after treatment for localized prostate cancer. N Engl J Med. Jan. 31. 2013;368(5):436-45. [pmid: 23363497].
56 Magheli A, Gonzalgo ML, Su LM, et al. Impact of surgical technique (open vs laparoscopic vs robotic-assisted) on pathological and biochemical outcomes following radical prostatectomy: an analysis using propensity score matching. BJU Int. Jun. 2011;107(12):1956-62. [pmid: 21044243].
57 Williams SB, Lei Y, Nguyen PL, et al. Comparative effectiveness of cryotherapy vs brachytherapy for localised prostate cancer. BJU Int. Jul. 2012;110(2 Pt 2):E92-8. [pmid: 22192688].
58 Sheets NC, Goldin GH, Meyer AM, et al. Intensity-modulated radiation therapy, proton therapy, or conformal radiation therapy and morbidity and disease control in localized prostate cancer. JAMA. Apr. 18. 2012;307(15):1611-20. [pmid: 22511689].
59 Abdollah F, Sun M, Schmitges J, et al. Competing-risks mortality after radiotherapy vs. observation for localized prostate cancer: a population-based study. Int J Radiat Oncol Biol Phys. Sep. 1. 2012;84(1):95-103. [pmid: 22330991].
60 Kim S, Shen S, Moore DF, et al. Late gastrointestinal toxicities following radiation therapy for prostate cancer. Eur Urol. Nov. 2011;60(5):908-16. [pmid: 21684064].
61 Ferrer M, Suarez JF, Guedea F, et al. Health-related quality of life 2 years after treatment with radical prostatectomy, prostate brachytherapy, or external beam radiotherapy in patients with clinically localized prostate cancer. Int J Radiat Oncol Biol Phys. Oct. 1. 2008;72(2):421-32. [pmid: 18325680].
62 Ploussard G, de la Taille A, Moulin M, et al. Comparisons of the perioperative, functional, and oncologic outcomes after robot-assisted versus pure extraperitoneal laparoscopic radical prostatectomy. Eur Urol. Mar. 2014;65(3):610-9. Epub 2012 Dec 1. [pmid: 23245815].
63 Sumitomo M, Hayashi M, Watanabe T, et al. Efficacy of short-term androgen deprivation with high-intensity focused ultrasound in the treatment of prostate cancer in Japan. Urology. Dec. 2008;72(6):1335-40. [pmid: 18355899].
64 Barocas DA, Salem S, Kordan Y, et al. Robotic assisted laparoscopic prostatectomy versus radical retropubic prostatectomy for clinically localized prostate cancer: comparison of short-term biochemical recurrence-free survival. J Urol. Mar. 2010;183(3):990-6. [pmid: 20083261].
65 Krambeck AE, DiMarco DS, Rangel LJ, et al. Radical prostatectomy for prostatic adenocarcinoma: a matched comparison of open retropubic and robot-assisted techniques. BJU Int. Feb. 2009;103(4):448-53. [pmid: 18778350].
66 Barry MJ, Gallagher PM, Skinner JS, et al. Adverse effects of robotic-assisted laparoscopic versus open retropubic radical prostatectomy among a nationwide random sample of medicare-age men. J Clin Oncol. Feb. 10. 2012;30(5):513-8. [pmid: 22215756].
67 Silberstein JL, Su D, Glickman L, et al. A case-mix-adjusted comparison of early oncological outcomes of open and robotic prostatectomy performed by experienced high volume surgeons. BJU Int. Feb. 2013;111(2):206-12. [pmid: 23356747].
68 Alemozaffar M, Sanda M, Yecies D, et al. Benchmarks for operative outcomes of robotic and open radical prostatectomy: results from the health professionals follow-up study. Eur Urol. 2014. Feb. 11. Epub ahead of print. [pmid: 24582327].
69 Masterson TA, Cheng L, Boris RS, et al. Open vs. robotic-assisted radical prostatectomy: a single surgeon and pathologist comparison of pathologic and oncologic outcomes. Urol Oncol. Oct. 2013;31(7):1043-8. Epub 2012 Jan 4. [pmid: 22222059].
70 Pierorazio PM, Mullins JK, Eifler JB, et al. Contemporaneous comparison of open vs minimally-invasive radical prostatectomy for high-risk prostate cancer. BJU Int. Oct. 2013;112(6):751-7. [pmid: 23356390].
71 Malcolm JB, Fabrizio MD, Barone BB, et al. Quality of life after open or robotic prostatectomy, cryoablation or brachytherapy for localized prostate cancer. J Urol. May. 2010;183(5):1822-8. [pmid: 20303100].
72 Abdollah F, Sun M, Schmitges J, et al. Cancer-specific and other-cause mortality after radical prostatectomy versus observation in patients with prostate cancer: competing-risks analysis of a large North American population-based cohort. Eur Urol. Nov. 2011;60(5):920-30. [pmid: 21741762].
73 Hadley J, Yabroff KR, Barrett MJ, et al. Comparative effectiveness of prostate cancer treatments: evaluating statistical adjustments for confounding in observational data. J Natl Cancer Inst. Dec. 1. 2010;102(23):1780-93. [pmid: 20944078].
74 Wirth GJ, Psutka SP, Chapin BF, et al. Midterm oncological outcomes of laparoscopic vs open radical prostatectomy (RP). BJU Int. Jul. 2013;112(2):190-7. [pmid: 23601185].
75 Kibel AS, Ciezki JP, Klein EA, et al. Survival among men with clinically localized prostate cancer treated with radical prostatectomy or radiation therapy in the prostate specific antigen era. J Urol. Apr. 2012;187(4):1259-65. [pmid: 22335870].
76 Rosenberg JE, Chen MH, Nguyen PL, et al. Hormonal therapy or external-beam radiation with brachytherapy and the risk of death from prostate cancer in men with intermediate risk prostate cancer. Clin Genitourin Cancer. Mar. 2012;10(1):21-5. [pmid: 22130293].
77 Spratt DE, Zumsteg ZS, Ghadjar P, et al. Comparison of high-dose (86.4 Gy) IMRT vs combined brachytherapy plus IMRT for intermediate-risk prostate cancer. BJU Int. 2013. Oct. 15. Epub ahead of print. [pmid: 24447404].
78 Lu-Yao GL, Albertsen PC, Moore DF, et al. Survival following primary androgen deprivation therapy among men with localized prostate cancer. JAMA. Jul. 9. 2008;300(2):173-81. [pmid: 18612114].
79 Liu J, Shi L, Sartor O, et al. Androgen-deprivation therapy versus radical prostatectomy as monotherapy among clinically localized prostate cancer patients. Onco Targets Ther. 2013;6:725-32. [pmid: 23836984].
80 Mohammed N, Kestin L, Ghilezan M, et al. Comparison of acute and late toxicities for three modern high-dose radiation treatment techniques for localized prostate cancer. Int J Radiat Oncol Biol Phys. Jan. 1. 2012;82(1):204-12. [pmid: 21167653].
81 Bekelman JE, Mitra N, Efstathiou J, et al. Outcomes after intensity-modulated versus conformal radiotherapy in older men with nonmetastatic prostate cancer. Int J Radiat Oncol Biol Phys. Nov. 15. 2011;81(4):e325-34. [pmid: 21498008].
82 Dosoretz AM, Chen MH, Salenius SA, et al. Mortality in men with localized prostate cancer treated with brachytherapy with or without neoadjuvant hormone therapy. Cancer. Feb. 15. 2010;116(4):837-42. [pmid: 20052734].
83 Nanda A, Chen MH, Moran BJ, et al. Neoadjuvant hormonal therapy use and the risk of death in men with prostate cancer treated with brachytherapy who have no or at least a single risk factor for coronary artery disease. Eur Urol. Jan. 2014;65(1):177-85. Epub 2012 Sep 7. [pmid: 22981136].
84 Shen X, Keith SW, Mishra MV, et al. The impact of brachytherapy on prostate cancer-specific mortality for definitive radiation therapy of high-grade prostate cancer: a population-based analysis. Int J Radiat Oncol Biol Phys. Jul. 15. 2012;83(4):1154-9. [pmid: 22270175].
85 Sanda MG, Dunn RL, Michalski J, et al. Quality of life and satisfaction with outcome among prostate-cancer survivors. N Engl J Med. Mar. 20. 2008;358(12):1250-61. [pmid: 18354103].
86 Marina O, Gustafson GS, Kestin LL, et al. Comparison of dose-escalated, image-guided radiotherapy vs. dose-escalated, high-dose-rate brachytherapy boost in a modern cohort of intermediate-risk prostate cancer patients. Brachytherapy. Jan-Feb. 2014;13(1):59-67. Epub 2013 Jul 18. [pmid: 23871661].
87 D'Amico AV, Chen MH, Catalona WJ, et al. Prostate cancer-specific mortality after radical prostatectomy or external beam radiation therapy in men with 1 or more high-risk factors. Cancer. Jul. 01. 2007;110(1):56-61. [pmid: 17530618].
88 Wong WW, Vora SA, Schild SE, et al. Radiation dose escalation for localized prostate cancer: intensity-modulated radiotherapy versus permanent transperineal brachytherapy. Cancer. Dec. 1. 2009;115(23):5596-606. [pmid: 19670452].
89 Zelefsky MJ, Chou JF, Pei X, et al. Predicting biochemical tumor control after brachytherapy for clinically localized prostate cancer: The Memorial Sloan-Kettering Cancer Center experience. Brachytherapy. Jul-Aug. 2012;11(4):245-9. [pmid: 21925957].
90 Abern MR, Dude AM, Tsivian M, et al. The characteristics of bladder cancer after radiotherapy for prostate cancer. Urol Oncol. Nov. 2013;31(8):1628-34. Epub 2012 May 9. [pmid: 22575239].
91 Ferrer M, Guedea F, Suarez JF, et al. Quality of life impact of treatments for localized prostate cancer: cohort study with a 5 year follow-up. Radiother Oncol. Aug. 2013;108(2):306-13. Epub 2013 Jul 9. [pmid: 23849168].
92 Sugihara T, Yasunaga H, Horiguchi H, et al. Comparisons of perioperative outcomes and costs between open and laparoscopic radical prostatectomy: a propensity-score matching analysis based on the Japanese Diagnosis Procedure Combination database. Int J Urol. Mar. 2013;20(3):349-53. [pmid: 23320826].
93 United States Government Accountability Office. Medicare: higher use of costly prostate cancer treatment by providers who self-refer warrants scrutiny. Report to Congressional Requesters. [GAO-13-525]. Washington (DC). United States Government Accountability Office. 2013. Jul. 44 p. Also available: www.gao.gov/assets/660/656026.pdf.
94 Bill-Axelson A, Holmberg L, Ruutu M, et al. Radical prostatectomy versus watchful waiting in early prostate cancer. N Engl J Med. May. 12. 2005;352(19):1977-84. [pmid: 15888698].
95 Iversen P, Madsen PO, Corle DK. Radical prostatectomy versus expectant treatment for early carcinoma of the prostate. Twenty-three year follow-up of a prospective randomized study. Scand J Urol Nephrol Suppl. 1995;172:65-72. [pmid: 8578259].
96 D'Amico AV, Manola J, Loffredo M, et al. 6-month androgen suppression plus radiation therapy vs radiation therapy alone for patients with clinically localized prostate cancer: a randomized controlled trial. JAMA. Aug. 18. 2004;292(7):821-7. [pmid: 15315996].
97 Denham JW, Steigler A, Lamb DS, et al. Short-term androgen deprivation and radiotherapy for locally advanced prostate cancer: results from the Trans-Tasman Radiation Oncology Group 96.01 randomised controlled trial. Lancet Oncol. Nov. 2005;6(11):841-50. [pmid: 16257791].
98 Atkins D, Chang S, Gartlehner G, et al. Assessing the applicability of studies when comparing medical intervention. [AHRQ Publication No. 11-EHC019-EF]. Methods guide for effectiveness and comparative effectiveness reviews. Rockville (MD). Agency for Healthcare Research and Quality. 2011. Jan. [pmid: 21433409].