# Methods

This section documents the methods we used to conduct and produce this updated systematic review on therapies for clinically localized prostate cancer for the Agency for Healthcare Research and Quality (AHRQ) through its Effective Health Care Program (www.effectivehealthcare.ahrq.gov).

The methods used for preparing the 2008 systematic review were developed through a rigorous process by the University of Minnesota Evidence-based Practice Center (EPC) in consultation with AHRQ and a Technical Expert Panel.22 We incorporated the methods from the original report when possible. However, for this update, our methods were informed by a more recent version of the guidance from the “Methods Guide for Effectiveness and Comparative Effectiveness Reviews,”26 hereafter referred to as the Methods Guide. The search strategy was based on that composed for the 2008 report, but we incorporated newer search methods and reflected changes in the relevant nomenclature, such as differentiating AS from WW. We used similar criteria and methods as in the 2008 report for study selection, data extraction, and risk-of-bias assessment for studies published since January 2007. The strength of evidence for each outcome was assessed according to more recent guidance from the Methods Guide.26

## Literature Search Strategy

Medical Librarians in the ECRI Institute–Penn Medicine EPC Information Center performed literature searches, following established systematic review protocols. We searched the following databases using controlled vocabulary and text words: EMBASE, MEDLINE, PubMed, and The Cochrane Library from January 1, 2007, through March 7, 2014. The literature searches were updated during the peer review process, before finalization of the review. The full search strategy is provided in Appendix A.

Literature screening (for reviews or studies) was performed in duplicate using the database Distiller SR (Evidence Partners, Ottawa, Ontario, Canada). Initially, we screened literature search results in duplicate for relevancy. We screened relevant abstracts again, in duplicate, against the inclusion criteria. Studies that appeared to meet the inclusion criteria were retrieved in full, and we screened them again, in duplicate, against the inclusion criteria. All disagreements were resolved by consensus discussion among the two original screeners and, if necessary, an additional third screener. We used Reference Manager™ software (Thomson Reuters, New York, NY) for managing references.

## Inclusion and Exclusion Criteria

We used the same study selection criteria as in the 2008 report (see Table 6, Table 7, Table 8, and Table 9). For Key Questions (KQs) 1, 2, and 4, we included randomized trials only if the randomized treatment allocation was based on men with clinically localized disease and if clinical outcomes were reported for T1–T3a disease separately from T3b and T4 disease. We also included large nonrandomized comparative studies (N≥500) that controlled for potentially confounding variables.

Table 6 Inclusion criteria: Key Question 1

Question Components | Inclusion Criteria
Major treatment options of interest:; - Radical prostatectomy (retropubic, perineal, laparoscopic, robotic-assisted); - External beam radiotherapy; - Interstitial brachytherapy; - Hormonal therapy; - Watchful waiting and active surveillance; Emerging treatment options of interest:; - Cryotherapy; - High-intensity focused ultrasound therapy (premarket approval application for 1 device is under consideration by the U.S. Food and Drug Administration); - Proton beam therapy; - Stereotactic body radiation therapy; Outcomes of interest:; - Overall mortality and morbidity; - Prostate-related mortality and morbidity; - Progression to metastasis; - Biochemical recurrence; - Quality of life; - Adverse effects such as urinary incontinence and sexual dysfunction | RCTs comparing different treatment options that enrolled patients with clinically localized disease and reported outcomes of interest with duration of followup 1 year or more. Trials must have focused on, or provided separate analyses for men with clinically localized prostate cancer (T1–T3a). RCTs that assigned treatments based on pathological staging (i.e., based on intraoperative findings) rather than clinical staging were excluded. Large nonrandomized comparative studies (n≥500) that prospectively enrolled consecutive patients. For any nonrandomized comparative studies, we included only those that used an analytic method to address selection bias (propensity scoring, instrumental variable analysis, or preplanned multivariate regression). The treatments being compared must have been administered during the same time period, so that any observed difference between outcomes were not attributable to differential time frames. For adverse events, we also included large nonrandomized comparative studies (n≥500) that reported relevant data. Studies could be prospective or retrospective; however, to reduce the risk of bias, retrospective studies must have used consecutive enrollment or enrollment of a random sample of eligible participants. Studies must have been published in English. Studies comparing different surgical techniques, such as radical prostatectomy with or without nerve-sparing, or the same type of radiation but at different dosages were outside the scope of this report.

Abbreviation: RCT=Randomized controlled trial.

Table 7 Inclusion criteria: Key Question 2

Question Components | Inclusion Criteria
Effectiveness outcomes according to patient characteristics (age, race/ethnicity, comorbid conditions, and preferences) | Studies that met the inclusion criteria for Key Question 1 and reported outcomes stratified according to patient characteristics.

Table 8 Inclusion criteria: Key Question 3

Question Components | Inclusion Criteria
- Association between physician characteristics (specialty, experience) and patient outcomes; - Association between geographic region and patient outcomes; - Association between hospital characteristics (case volume, university vs. community) and patient outcomes | Randomized controlled trials or large multicentered nonrandomized studies that compared the effectiveness of radical prostatectomy to another treatment of interest and assessed how the effectiveness of these treatments varied by geographic region, type of hospital (university vs. community), case volume, or physician experience. Studies were excluded if there was insufficient detail regarding provider characteristics to inform this report.

Table 9 Inclusion criteria: Key Question 4

Question Components | Inclusion Criteria
Effectiveness outcomes according to tumor characteristics (prostate-specific antigen, tumor stage, histologic grade, tumor risk strata) | Studies that met the inclusion criteria for Key Question 1 and reported outcomes stratified according to tumor characteristics.

For KQ 3, we considered multicenter studies that compared radical prostatectomy (RP) with another treatment of interest, enrolled 500 or more patients, used appropriate statistical techniques to control for potentially confounding variables, and examined the effect of provider characteristics on survival of localized prostate cancer patients.

Non-English-language studies were excluded. Moher et al.27 have demonstrated that exclusion of non-English-language studies from meta-analyses has little impact on the conclusions drawn. Juni et al.28 found that non-English-language studies typically were of lower methodologic quality and that excluding them had little effect on effect-size estimates in the majority of meta-analyses they examined. Although we recognize that in some situations exclusion of non-English-language studies could lead to bias, we believe that the few instances in which this may occur do not justify the time and cost typically necessary to translate studies to identify those of acceptable quality for inclusion in our review.27,28

## PICOTS Criteria

### Population

- KQs 1–4: Men considered to have clinically localized prostate cancer (T1–T3a, N0–X, M0–X) regardless of age, histologic grade, or prostate-specific antigen (PSA) level. Articles were excluded if more than 15 percent of men with disease stage higher than T3a were enrolled and the study did not specifically report separate data for men with T1, T2, and/or T3a prostate cancer (see Tables 1–3).

### Interventions

- For KQs 1, 2, 4, we included treatment options for men with clinically localized prostate cancer: RP (including retropubic, perineal, laparoscopic, robotic-assisted), external beam radiation therapy (including conventional radiation, intensity-modulated radiation therapy, three-dimensional conformal radiotherapy, proton beam, and stereotactic body radiation therapy), interstitial brachytherapy, cryotherapy, watchful waiting, active surveillance, hormonal therapy, and high-intensity focused ultrasound.
- For KQ 3, we included RP (including retropubic, perineal, laparoscopic, robotic-assisted).

### Comparators

- Any of the interventions of interest above.

### Outcomes

- For KQ 1, 2, and 4, the primary outcome is overall mortality or survival. Additional outcomes include prostate cancer–specific mortality or survival, biochemical (PSA) progression, metastatic and/or clinical progression-free survival, health status, and quality of life. We focused primarily on common and severe adverse events of treatment including bowel, bladder, and sexual dysfunction, as well as harms from biopsy such as bleeding and nosocomial infections.
- For KQ 3, we examined overall-and prostate cancer–specific survival.

### Timing

- Duration of followup was a minimum of 1 year.

### Settings

- No restrictions by setting.

## Data Abstraction

We used the DistillerSR^®^ (Evidence Partners, Inc., Ottawa, Ontario, Canada) Web-based systematic review software for abstract screening. Data were extracted directly into a Word document by one team member and reviewed by a second team member. The data extracted included study, patient, tumor, and intervention characteristics and predefined outcomes. Standard errors, regression coefficients, and 95 percent confidence interval (95% CI) were calculated from reported means, standard deviations, and sample size when provided/appropriate.29 Summary measures included risk ratios, hazard ratios, odds ratios, absolute risk reduction, difference in means, and standardized mean difference. Also, because of the possibility of subjective interpretation, the risk-of-bias items were judged in duplicate. We resolved all discrepancies through discussion. Multiple publications of the same study (e.g., publications reporting subgroups, other outcomes, longer followup) were identified by examining author affiliations, study designs, enrollment criteria, and enrollment dates. Multiple publications were used only when each publication had unique data not reported in the most comprehensive and recent publication.

## Risk-of-Bias Evaluation

As stated above, because of the possibility of subjective interpretation, assessment of methodologic risk of bias of individual studies was performed by two researchers for each study, and discrepancies were resolved by consensus. When consensus could not be reached, a third researcher adjudicated.

We assessed the risk of bias by following the guidelines in the chapter, “Assessing the Risk of Bias of Individual Studies When Comparing Medical Interventions” in the “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”30 This involved evaluating several items such as randomization, allocation concealment, intention-to-treat-analysis, and completeness of followup (see Table 10). Additionally, we assessed fidelity to the protocol to address performance bias and blinding of outcome assessors to address detection bias when outcomes were subjective (as defined in Table 10). Each of these items was answered “Yes,” “No,” or “Not reported.”

Table 10 Risk of bias of included studies

Item | Comment
1. Were patients randomly or pseudorandomly (e.g., using instrumental variable analysis) assigned to the study groups? | Instrumental variable analysis can account for both measured and unmeasured confounders, as long as the chosen variables have a strong association with treatment choice but no association with health outcomes. Studies using this method received a “yes” for this item. Studies using propensity scoring or multivariate regression received a “no”.
2 Was there concealment of group allocation? | —
3 Were data analyzed based on the intention-to-treat-principle? | —
4 Were those who assessed the patient outcomes blinded to the group to which the patients were assigned? | —
5 Was the outcome measure of interest objective and was it objectively measured? | The following were considered objective outcomes: overall mortality or survival, prostate cancer–specific survival, adverse events, biochemical progression–free survival. The following were considered subjective outcomes: quality of life and health status (morbidity).
6 Was there a 15% or less difference in the length of followup for the 2 groups? | —
7 Did 85% or more of enrolled patients provide data at the time point of interest? | —
8 Was there fidelity to the protocol?

We used the same checklist to rate the risk of bias for both RCTs and nonrandomized comparative studies. We considered this appropriate because any study with parallel treatment comparisons is subject to the same set of biases, and randomization is a method designed to control for selection bias from both known and unknown confounders. Checklists specific for nonrandomized studies generally do not penalize studies for lack of randomization, which means the risk-of-bias rating tends to be artificially minimized in relation to RCTs that are rated using an RCT-specific checklist. Using the same checklist therefore ensures that both types of studies are judged using the same standards, and the relative ratings are therefore more accurate.

We categorized each study as having low, medium, or high risk of bias using the following method:

- To be considered as having low risk of bias, the study must meet all the following conditions:
  ○ There was randomization of study participants to treatment groups.
  ○ There was concealment of allocation.
  ○ Data analysis was based on the intention-to-treat-principle.
  ○ If outcome assessors were not blinded (item 4) or blinding of outcome assessors was not reported, then the outcome must have been objective (item 5).
  ○ There was a difference of 15 percent or less in the length of followup for the two groups.
  ○ Eighty-five percent or more of enrolled patients provided data at the time point of interest.
  ○ There was no clear indication of lack of fidelity to the protocol.
- To be considered as having high risk of bias, the study must meet at least one of the following criteria:
  ○ The trial was not randomized or pseudorandomized (i.e., using instrumental variables) and did not blind outcome assessors.
  ○ The trial had a difference of 15 percent or more in the length of followup for the two groups.
  ○ The trial authors specifically reported that they did not have good fidelity to the protocol.
- To be considered as having medium risk of bias, the study neither meets the criteria for low risk of bias nor the criteria for high risk of bias.

## Strength-of-Evidence Grading

We provided evidence grades (see Table 11) for the following outcomes: overall mortality or survival, prostate cancer–specific survival, progression to metastases and quality of life. We assessed strength of evidence by following the guidelines from the publication, “Grading the Strength of a Body of Evidence When Comparing Medical Interventions,” by Owens et al.31 We graded the strength of evidence for each major health outcome based on the following dimensions:

- Risk of bias (low, medium, or high)
- Consistency (consistent, inconsistent, or unknown/not applicable)
- Directness (direct or indirect)
- Precision (precise or imprecise)

Table 11 Strength-of-evidence grades and definitions

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, that is, another study would not change the conclusions.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

Two independent graders assessed each domain, and differences were resolved by consensus.

We assigned the strength of evidence an overall grade of high, moderate, low, or insufficient, as outlined by Owens et al. (see Table 11).31 The decision to grade an evidence base as insufficient rather than low often reflected an imprecise effect estimate (a nonstatistically significant effect with 95% CI wide enough to allow the possibility of a significant benefit for one treatment compared with another) in an evidence base with only one or two studies. However, we also graded as insufficient evidence from a single study with medium risk of bias or less than three consistent studies of high risk of bias, even when findings were direct and precise. Because multiple factors other than treatment can influence apparent differences between interventions, we placed a high value on replication of findings, even more so for studies with high risk of bias. Further explanation for this conservative approach to evidence grading appears in the Discussion section of the report.

When evidence came from subgroup analyses (KQs 2 and 4), the strength of evidence was lowered by one level. For example, when the strength of evidence for a primary analysis in KQ 1 was low, strength of evidence for subgroup analyses from the same studies was considered insufficient. We adopted this approach because subgroup analyses were usually underpowered to detect differences between treatments and sometimes not prespecified at the beginning of the study. In general, subgroup analyses should be considered as hypothesis-generating rather than definitive analyses.

## Applicability

Applicability was assessed by following the guidelines in “Assessing the Applicability of Studies When Comparing Medical Interventions,” by Atkins et al.32 The applicability of the evidence involves the following five aspects: patients, interventions, comparisons, outcomes, and settings.32 We addressed factors relevant to the applicability of the evidence by evaluating patient selection in both observational studies and clinical trials. We considered the primary biology and epidemiology (grade and stage of the prostate cancer) and the present-day clinical practice setting. The typical interventions, comparisons, outcomes (e.g., overall mortality, prostate cancer–specific survival), and settings of care were also used to more clearly specify the most applicable study characteristics (i.e., most typical of localized prostate cancer care in the United States).

## Data Synthesis

Because of the differences in study designs, treatments, patient and tumor characteristics, and reporting of outcomes, the 2008 report did not pool studies for KQs 1, 2, and 4. For the same reason, we performed only qualitative analysis in this update. RCTs and nonrandomized comparative studies differed substantially in average risk of bias, and we performed separate qualitative analyses and presented results separately for these study designs.

Study results were stratified based on study designs, comparisons across primary treatment categories, and comparisons within primary treatment categories.

Generally, we reported summaries of effectiveness and adverse-event outcomes with ranges according to treatment option, tumor characteristics, and group sample size. For KQ 1, we summarized and discussed comparative risks, benefits, and outcomes of therapies. For KQ 2, we summarized how patient characteristics affect outcomes. For KQ 4, we summarized how tumor characteristics affect outcomes. For KQ 3, we were unable to identify any studies that met our inclusion criteria.

## Peer Review and Publication

The review protocol was posted on March 29, 2013, at the AHRQ Effective Health Care Program Web site. The full draft report was posted for public and peer review comments from July 10, 2013 to August 6, 2013. Peer reviewers were invited to provide written comments on the draft report based on their clinical, content, or methodologic expertise. Peer review comments on the preliminary draft of the report were considered by the EPC in preparation of the final report. The dispositions of the peer review comments are documented and will be published 3 months after the publication of the evidence report.