# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Peter R. Carroll, M.D., M.P.H.
  Professor and Chair
  Department of Urology
  University of California, San Francisco
  San Francisco, CA
- Anthony V. D'Amico, M.D., Ph.D.
  Chief, Genitourinary Radiation Oncology
  Dana-Farber Cancer Institute
  Boston, MA
- Richard Hoffman, M.D., M.P.H., FACP
  Professor of Medicine
  University of New Mexico School of Medicine
  Albuquerque, NM
- Howard I. Scher, M.D.
  D. Wayne Calloway Chair in Urologic Oncology
  Chief, Genitourinary Oncology Service
  Department of Medicine
  Sidney Kimmel Center for Prostate and Urologic Cancers
  Memorial Sloan-Kettering Cancer Center
  Professor, Medicine
  Weill Cornell Medical College
  New York, NY