# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the ECRI Institute–Penn Medicine EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Michael J. Barry, M.D.
  Medical Director, Stoeckle Center for Primary Care Innovation
  Massachusetts General Hospital
  Boston, MA
- David I. Lee, M.D.
  Chief, Division of Urology
  Penn Presbyterian Medical Center
  Philadelphia, PA
- Andrew Loblaw, M.D., FRCPC, M.Sc.
  Professor & Clinician Scientist, Radiation Oncology
  Toronto Sunnybrook Regional Centre
  Toronto, Ontario, Canada
- Danil V. Makarov, M.D.
  Assistant Professor; Director, Urological Health Services Research
  Departments of Population Health & Urology
  NYU Langone Medical Center
  New York, NY
- Louis Potters, M.D., FACR, FASTRO
  Chairman and Professor, Department of Radiation Medicine
  Hofstra North Shore-LIJ School of Medicine
  North Shore-LIJ Health System
  Lake Success, NY
- Ian M. Thompson, M.D.
  Professor
  Glenda and Gary Woods Distinguished Chair in Genitourinary Oncology
  University of Texas Health Science Center
  San Antonio, TX
- Timothy J. Wilt, M.D., M.P.H.
  Core Investigator
  Minneapolis Veterans Affairs Center for Chronic Disease Outcomes Research
  Professor of Medicine
  University of Minnesota School of Medicine
  Minneapolis, MN