# Acknowledgments

The Evidence-based Practice Center would like to thank Eileen Erinoff, Kristi Yingling, and Helen Dunn for providing literature retrieval and documentation management support; Gina Giradi, Eloise DeHaan, and Lydia Dharia for their assistance with the final preparation of the report; Craig Umscheid for recruiting clinical coauthors and Technical Experts, and reviewing the protocol and portions of the final draft; and Justin Bekelman for his expert input on earlier drafts of this report.