# Ongoing Clinical Trials

Table G-1 Ongoing clinical trials retrieved from http://clinicaltrials.gov/ct2/home

Identifier | Sponsor | Design | Purpose | Start Date and Expected Completion Date
NCT00430183 | Cancer and Leukemia Group B, USA | RCT | This randomized phase III trial is studying docetaxel and leuprolide or goserelin to see how well they work when given before surgery compared with surgery alone in treating patients with high-risk localized prostate cancer | Start Date: December 2006 Estimated Completion Date: June 2018 Estimated Enrollment: 750
NCT01617161 | Massachusetts General Hospital, University of Pennsylvania, National Cancer Institute | RCT | This randomized phase III trial is studying whether men being treated for prostate cancer have the same amount of side effects from either 1 of 2 different external radiation treatments: intensity-modulated radiation therapy or proton beam therapy | Start Date: July, 2012 Estimated Completion Date: June 2016 Estimated Enrollment: 750
NCT01365143 | Mayo Clinic, USA | RCT | This study will prospectively randomize patients with localized prostate cancer who are candidates for surgical management to open vs. robotic radical prostatectomy. | Start Date: May 2011 Estimated Completion Date: May 2016 Estimated Enrollment: 454
NCT01492972 | Proton Collaborative Group, USA | RCT | This study will compare the use of hypofraction proton therapy (28 treatments) alone to proton therapy with androgen suppression therapy | Start Date: January 2012 Estimated Completion Date: December 2021 Estimated Enrollment: 192
NCT00116220 | Dana-Farber Cancer Institute, USA | RCT | To determine if the use of 6 months of total androgen suppression (hormonal therapy) when added to radiation therapy for localized-high risk prostate cancer would improve overall survival. | Start Date: September 1995 Estimated Completion Date: April 2014 Estimated Enrollment: 270
NCT00175383 | University of British Columbia, Canada | RCT | This study will compare short vs. long-acting luteinizing hormone–releasing hormone agonist preparation prior to transperineal implantation of the prostate. | Start Date: December 2004 Estimated Completion Date: June 2013 Estimated Enrollment: 100
NCT01584258 Prostate Advances in Comparative Evidence (PACE) | Accuray Inc., Switzerland Study is being conducted in France, Germany, the Netherlands and the United Kingdom | RCT | This study is an international multicenter randomized study of organ confined low and intermediate risk prostate cancer and is composed of 2 parallel randomization schemes based on applicability of surgery as a treatment for the patient. Patients for whom surgery is a consideration are randomized to either laparoscopic or da Vinci prostatectomy or CyberKnife prostate SBRT (also known as CyberKnife radiosurgery). Patients for whom surgery is not a consideration are randomized to either conventionally fractionated radiation therapy or CyberKnife prostate SBRT. Efficacy, toxicity and quality of life outcomes will be compared across the pairs in each randomization. | Start Date: April 2012 Estimated Completion Date: April 2025 Estimated Enrollment: 1,036
NCT01717677 Evaluation of Four Treatment Modalities in Prostate Cancer With Low or “Early Intermediate” Risk (PREFERE) | Association of Urogenital Oncology (AUO), Germany | RCT | 4 arms preference based study to compare four therapy options (radical prostatectomy, percutaneous radiation therapy, permanent seed brachytherapy, and active surveillance) in prostate cancer with low or early intermediate risk. | Start Date: October 2012 Estimated Completion Date: December 2030 Estimated Enrollment: 7,600

Abbreviations: RCT=Randomized controlled trial; SBRT=stereotactic body radiotherapy.

Table G-2 Ongoing clinical trial retrieved from www.epi.bris.ac.uk/protect/

Identifier | Sponsor | Design | Purpose | Start Date and Expected Completion Date
ProtecT (Prostate testing for cancer and Treatment) Study | Department of Health, United Kingdom | Randomized Controlled Trial | The study aims to evaluate treatments for localized prostate cancer. It is comparing surgery (radical prostatectomy), radiotherapy (radical conformal) and active monitoring (monitoring with regular check-ups). | Start date: June 1999 Estimated Completion Date: June 2013 Between June 2001 and October 2008, approximately 109,750 men have taken part in the ProtecT study.