# Evidence Tables

Table F-1 All-cause mortality (randomized controlled trials)

Table F-2 All-cause mortality (nonrandomized comparative studies)

Table F-3 Overall survival (randomized controlled trials)

Table F-4 Overall survival (nonrandomized comparative studies)

Table F-5 Prostate cancer–specific mortality (randomized controlled trials)

Table F-6 Prostate cancer–specific mortality and cause-specific survival (nonrandomized comparative studies)

Table F-7 Biochemical failure (randomized controlled trials)

Table F-8 Biochemical failure (nonrandomized comparative studies)

Table F-9 Biochemical progression–free survival (randomized controlled trials)

Table F-10 Biochemical progression–free survival (nonrandomized comparative studies)

Table F-11 Progression to metastasis (randomized controlled trials)

Table F-12 Progression to metastasis (nonrandomized comparative studies)

Table F-13 Quality of life (randomized controlled trials)

Table F-14 Quality of life (nonrandomized comparative studies)

Table F-15 Reported adverse events (randomized controlled trials)

Table F-16 Reported adverse events (nonrandomized comparative studies)