# Baseline Demographic and Tumor Characteristics

Table E-1 Baseline demographic and tumor characteristics (randomized controlled trials)

Table E-2 Baseline demographic and tumor characteristics (nonrandomized comparative studies)