# Key Questions 1–4: Study Selection Criteria and Description of Treatment

Table D-1 Description of study design and selection criteria and treatment (randomized controlled trials)

Table D-2 Description of study design and selection criteria and treatment (nonrandomized comparative studies)