# Risk of Bias Assessment for Key Question 1

Table C-1 Risk-of-bias assessment for Key Question 1 (randomized controlled trials)

Study | Outcome(s) | Were patients randomly or pseudorandomly (e.g. using instrumental variable analysis) assigned to the study groups? | Q2. Was there concealment of group allocation? | Q3. Were data analyzed based on the intention-to-treat-principle? | Q4. Were those who assessed the patient outcomes blinded to the group to which the patients were assigned? | Q5. Was the outcome measure of interest objective and was it objectively measured? | Q6. Was there a 15% or less difference in the length of followup for the two groups? | Q7. Did 85% or more of enrolled patients provide data at the time point of interest? | Q8. Was there fidelity to protocol? | Overall Risk of Bias Category
Porpiglia et al. 2012^45^ | BRFS AEs | Yes | NR | No | NR | Yes | Yes | Yes | NR | Medium
Porpiglia et al. 2012^45^ | QOL | Yes | NR | No | NR | No | Yes | Yes | NR | High
Wilt et al. 2012^25^ and Wilt et al. 2009^24^ Prostate Intervention Versus Observation Trial (PIVOT) | Overall mortality PCSM Distant metastases AEs | Yes | Yes | Yes | Yes | Yes | Yes | No | NR | Medium
Wilt et al. 2012^25^ and Wilt et al. 2009^24^ Prostate Intervention Versus Observation Trial (PIVOT) | QOL | Yes | Yes | Yes | Yes | No | Yes | No | NR | Medium
Bill-Axelson et al. 2013^48^, Bill-Axelson et al. 2011^33^, Johansson et al. 2011^51^, Holmberg et al. 2012^34^, and Bill-Axelson et al. 2008^15^ Scandinavian Prostate Cancer Group-4 (SPCG-4) Trial | Overall mortality PCSM Distant metastases AEs | Yes | Yes | Yes | Yes for PCSM, NR for other outcomes | Yes | Yes | No | NR | Medium
Bill-Axelson et al. 2013^48^, Bill-Axelson et al. 2011^33^, Johansson et al. 2011^51^, Holmberg et al. 2012^34^, and Bill-Axelson et al. 2008^15^ Scandinavian Prostate Cancer Group-4 (SPCG-4) Trial | QOL | Yes | Yes | Yes | NR | No | Yes | No | NR | High
Jones et al. 2011^43^ | Overall survival PCSM Biochemical failure Distant metastases AEs | Yes | NR | No | No | Yes | Yes | Yes | NR | Medium
Jones et al. 2011^43^ | QOL | Yes | NR | No | No | No | Yes | Yes | NR | High
Donnelly et al. 2010^47^ Same study as Robinson et al. 2009^52^ | Overall survival PCSM Biochemical failure AEs | Yes | NR | No | No | Yes | Yes | Yes | NR | Medium
Donnelly et al. 2010^47^ Same study as Robinson et al. 2009^52^ | QOL | Yes | NR | No | No | No | Yes | Yes | NR | High
Giberti et al. 2009^44^ | BDFS | Yes | Yes | NR | Yes | Yes | Yes | Yes | NR | Medium
Giberti et al. 2009^44^ | QOL | Yes | Yes | NR | Yes | No | Yes | Yes | NR | Medium
D'Amico et al. 2008^49^, D'Amico et al. 2008^35^ and Nguyen et al. 2010^53^ | Overall mortality PCSM AEs | Yes | Yes | Yes | NR | Yes | Yes | Yes | NR | Low
D'Amico et al. 2008^49^, D'Amico et al. 2008^35^, and Nguyen et al. 2010^53^ | QOL | Yes | Yes | Yes | Yes | No | Yes | Yes | NR | Low
Martis et al. 2007^46^ | AEs | Yes | NR | NR | NR | Yes | Yes | Yes | NR | Medium
Martis et al. 2007^46^ | QOL | Yes | NR | NR | NR | No | Yes | Yes | NR | High

Abbreviations: AEs=adverse events, BDFS=biochemical disease free survival, BRFS=biochemical recurrence free survival, NR=not reported, OS=overall survival, PCSM=prostate cancer specific mortality, QOL=quality of life

Table C-2 Risk-of-bias assessment for Key Question 1 (nonrandomized comparative studies)

Study | Outcome(s) | Were patients randomly or pseudorandomly (e.g. using instrumental variable analysis) assigned to the study groups? | Q2. Was there concealment of group allocation? | Q3. Were data analyzed based on the intention-to-treat-principle? | Q4. Were those who assessed the patient outcomes blinded to the group to which the patients were assigned? | Q5. Was the outcome measure of interest objective and was it objectively measured? | Q6. Was there a 15% or less difference in the length of followup for the two groups? | Q7. Did 85% or more of enrolled patients provide data at the time point of interest? | Q8. Was there fidelity to protocol? | Overall Risk of Bias Category
Alemozaffar et al. 2014^68^ | PCSM Progression to metastasis BRFS | No | No | No | No | Yes | No | No | NR | High
Alemozaffar et al. 2014^68^ | QOL | No | No | No | No | No | No | No | NR | High
Mukherjee et al. 2014^37^ | All cause mortality PCSM AEs | No | No | No | No | Yes | No | Yes | NR | High
DeGroot et al. 2013^41^ | PCSM | No | No | No | No | Yes | Yes | Yes | NR | High
Ferrer et al. 2013^91^ Same study as Ferrer et al. 2008^61^ | All-cause mortality Biochemical recurrence-free survival | No | No | No | No | Yes | Yes | Yes | NR | High
Ferrer et al. 2013^91^ Same study as Ferrer et al. 2008^61^ | QOL | No | No | No | No | No | Yes | Yes | NR | High
Hoffman et al. 2013^38^ | All-cause mortality PCSM | No | No | No | No | Yes | Yes | Yes | NR | High
Liu et al. 2013^79^ | All-cause mortality PCSM | No | No | No | No | Yes | Yes | Yes | NR | High
Marina et al. 2013^86^ | Overall survival Cause-specific survival Biochemical failure Biochemical recurrence-free survival Clinical progression | No | No | No | No | Yes | Yes | Yes | NR | High
Nepple et al. 2013^40^ | All-cause mortality PCSM | No | No | No | No | Yes | Yes | Yes | NR | High
Pierorazio et al. 2013^70^ | BRFS | No | No | No | No | Yes | Yes | Yes | NR | High
Resnick et al. 2013^55^ | QOL (Urinary function, bowel function, sexual function) | No | No | No | No | No | Yes | Yes | NR | High
Silberstein et al. 2013^67^ | BRFS | No | No | No | No | Yes | Yes | Yes | NR | High
Spratt et al. 2013^77^ | AEs | No | No | No | No | Yes | Yes | Yes | NR | High
Spratt et al. 2013^77^ | QOL | No | No | No | No | No | Yes | Yes | NR | High
Wirth et al. 2013^74^ | BRFS | No | No | No | No | Yes | Yes | Yes | NR | High
Abdollah et al. 2012^59^ | PCSM | No | No | No | No | Yes | Yes | Yes | NR | High
Abern et al. 2012^90^ | AEs | No | No | No | No | Yes | Yes | Yes | NR | High
Barry et al. 2012^66^ | QOL (Continence, sexual function) | No | No | No | No | No | Yes | Yes | NR | High
Kibel et al. 2012^75^ | Overall survival PCSM | No | No | No | No | Yes | Yes | Yes | NR | High
Mohammed et al. 2012^80^ | AEs | No | No | No | No | Yes | Yes | Yes | NR | High
Mohammed et al. 2012^80^ | QOL | No | No | No | No | No | Yes | Yes | NR | High
Nanda et al. 2012^83^ | AEs | No | No | No | No | Yes | Yes | Yes | NR | High
Ploussard et al. 2012^62^ | BRFS Biochemical recurrence AEs | No | No | No | NR | Yes | No | Yes | NR | High
Ploussard et al. 2012^62^ | QOL | No | No | No | NR | No | No | Yes | NR | High
Rosenberg et al. 2012^76^ | PCSM | No | No | No | No | Yes | Yes | Yes | NR | High
Sheets et al. 2012^58^ | AEs | Yes | No | No | No | Yes | Yes | Yes | NR | Medium
Sheets et al. 2012^58^ | QOL | Yes | No | No | No | No | Yes | Yes | NR | High
Shen et al. 2012^84^ | PCSM | No | No | No | No | Yes | Yes | Yes | NR | High
Zelefsky et al. 2012^89^ | BRFS | No | No | No | No | Yes | Yes | Yes | NR | High
Abdollah et al. 2011^72^ | PCSM Other cause mortality | No | No | No | No | Yes | Yes | Yes | NR | High
Bekelman et al. 2011^81^ | AEs | No | No | No | No | Yes | Yes | Yes | NR | High
Kim et al. 2011^60^ | AEs | No | No | No | No | Yes | Yes | No | NR | High
Masterson et al. 2011^69^ | BRFS | No | No | No | No | Yes | No | Yes | NR | High
Rice et al. 2011^36^ | Overall mortality Biochemical recurrence | No | No | No | No | Yes | No | Yes | NR | High
Williams et al. 2011^57^ | AEs | No | No | No | No | Yes | Yes | Yes | NR | High
Williams et al. 2011^57^ | QOL | No | No | No | No | No | Yes | Yes | NR | High
Barocas et al. 2010^64^ | BRFS | No | No | No | No | Yes | Yes | Yes | NR | High
Cooperberg et al. 2010^39^ | All-cause mortality PCSM | No | No | No | No | Yes | Yes | Yes | NR | High
Dosoretz et al. 2010^82^ | All-cause mortality | No | No | No | No | Yes | Yes | Yes | NR | High
Hadley et al. 2010^73^ | All cause mortality PCSM | Yes | No | No | No | Yes | Yes | Yes | NR | Medium
Magheli et al. 2010^56^ | Biochemical recurrence | No | No | No | No | Yes | Yes | Yes | NR | High
Wong et al. 2009^88^ | Biochemical recurrence Distant metastases AEs | No | No | No | No | Yes | Yes | Yes | NR | High
Malcolm et al. 2009^71^ | QOL | No | No | No | No | No | Yes | No | NR | High
Krambeck et al. 2008^65^ | PCSM Other cause mortality Biochemical progression Systemic progression Clinical local recurrence AEs | No | No | No | No | Yes | Yes | Yes | NR | High
Krambeck et al. 2008^65^ | QOL | No | No | No | No | No | Yes | Yes | NR | High
Lu-Yao et al. 2008^78^ | Overall survival PCSS | Yes | No | No | No | Yes | Yes | Yes | NR | Medium
Sanda et al. 2008^41^ | QOL | No | No | No | No | No | Yes | No | NR | High
Schroeck et al. 2008^54^ | PSA recurrence rate | No | No | No | No | Yes | Yes | Yes | NR | High
Sumitomo et al. 2008^63^ | BPFS AEs | No | No | No | No | Yes | Yes | Yes | NR | High
Sumitomo et al. 2008^63^ | QOL | No | No | No | No | No | Yes | Yes | NR | High
Albertsen et al. 2007^42^ | Overall survival PCSM | No | No | No | No | Yes | Yes | Yes | NR | High
D'Amico et al. 2007^87^ | PCSM | No | No | No | No | Yes | Yes | Yes | NR | High

Abbreviations: AEs=adverse events, BPFS=biochemical progression free survival, BRFS=biochemical recurrence free survival, NR=not reported, PCSM=prostate cancer specific mortality, PCSS=prostate cancer–specific survival, PSA=prostate specific antigen, QOL=quality of life.