# Full-Length Review Excluded Studies

## Randomized controlled trials (RCTs) with a mixed population (≥15% of patient population had T3 [not reporting T3a separately from T3b], T3b, or T4, or metastatic cancer and did not report separate data for T1 or T2 or T3a)

Bolla M, de Reijke TM, Van Tienhoven G, et al. Duration of androgen suppression in the treatment of prostate cancer. N Engl J Med. Jun. 11. 2009;360(24):2516-27. [pmid: 19516032].
Bolla M, van Poppel H, Tombal B, et al. Postoperative radiotherapy after radical prostatectomy for high-risk prostate cancer: long-term results of a randomised controlled trial (EORTC trial 22911). Lancet. Dec. 8. 2012;380(9858):2018-27. [pmid: 23084481].
Bolla M, Van Tienhoven G, Warde P, et al. External irradiation with or without long-term androgen suppression for prostate cancer with high metastatic risk: 10-year results of an EORTC randomised study. Lancet Oncol. Nov. 2010;11(11):1066-73. [pmid: 20933466].
Creak A, Hall E, Horwich A, et al. Randomised pilot study of dose escalation using conformal radiotherapy in prostate cancer: Long-term follow-up. Br J Cancer. 2013;109(3):651-7. [pmid: 23880826].
D'Amico AV, Chen MH, Crook J, et al. Duration of short-course androgen suppression therapy and the risk of death as a result of prostate cancer. J Clin Oncol. Dec. 10. 2011;29(35):4682-7. [pmid: 22042952].
Danuser H, Pierro GB, Stucki P, et al. Extended pelvic lymphadenectomy and various radical prostatectomy techniques: Is pelvic drainage necessary?. BJU Int. 2013;111(6):963-9. [pmid: 23356829].
Dearnaley DP, Sydes MR, Langley RE, et al. The early toxicity of escalated versus standard dose conformal radiotherapy with neo-adjuvant androgen suppression for patients with localised prostate cancer: results from the MRC RT01 trial (ISRCTN47772397). Radiother Oncol. Apr. 2007;83(1):31-41. [pmid: 17391791].
Denham JW, Nowitz M, Joseph D, et al. Impact of androgen suppression and zoledronic acid on bone mineral density and fractures in the Trans-Tasman Radiation Oncology Group (TROG) 03.04 Randomised Androgen Deprivation and Radiotherapy (RADAR) randomized controlled trial for locally advanced prostate cancer. BJU Int. 2013. Oct. 15. Epub ahead of print. [pmid: 24512527].
Denham JW, Steigler A, Tai KH, et al. Paradoxical metastatic progression following 3 months of neo-adjuvant androgen suppression in the TROG 96.01 trial for men with locally advanced prostate cancer. Radiother Oncol. May. 2013;107(2):123-8. [pmid: 23618502].
Donnelly BJ, Saliken JC, Brasher PM, et al. A randomized trial of external beam radiotherapy versus cryoablation in patients with localized prostate cancer. Cancer. Jan. 15. 2010;116(2):323-30. [pmid: 19937954].
Horwitz EM, Bae K, Hanks GE, et al. Ten-year follow-up of radiation therapy oncology group protocol 92-02: a phase III trial of the duration of elective androgen deprivation in locally advanced prostate cancer. J Clin Oncol. May. 20. 2008;26(15):2497-504. [pmid: 18413638].
Hoskin PJ, Rojas AM, Bownes PJ, et al. Randomised trial of external beam radiotherapy alone or combined with high-dose-rate brachytherapy boost for localised prostate cancer. Radiother Oncol. May. 2012;103(2):217-22. [pmid: 22341794].
Hoskin PJ, Rojas AM, Ostler PJ, et al. Quality of life after radical radiotherapy for prostate cancer: longitudinal study from a randomised trial of external beam radiotherapy alone or in combination with high dose rate brachytherapy. Clin Oncol (R Coll Radiol). May. 2013;25(5):321-7. [pmid: 23384799].
Khor R, Duchesne G, Tai KH, et al. Direct 2-arm comparison shows benefit of high-dose-rate brachytherapy boost vs external beam radiation therapy alone for prostate cancer. Int J Radiat Oncol Biol Phys. 2013;85(3):679-85. [pmid: 22954770].
Klotz L, Miller K, Crawford ED, et al. Disease control outcomes from analysis of pooled individual patient data from five comparative randomised clinical trials of degarelix versus luteinising hormone-releasing hormone agonists. Eur Urol. 2014. Jan. 9. Epub ahead of print. [pmid: 24440304].
Lund JA, Kaa SA, Wibe A, et al. Late radiation effects to the rectum and anus after treatment for prostate cancer; Validity of the LENT/SOMA score. Acta Oncol. May. 2013;52(4):727-35. [pmid: 23398595].
Mason M, Maldonado Pijoan X, Steidle C, et al. Neoadjuvant androgen deprivation therapy for prostate volume reduction, lower urinary tract symptom relief and quality of life improvement in men with intermediate- to high-risk prostate cancer: a randomised non-inferiority trial of degarelix versus goserelin plus bicalutamide. Clin Oncol. Mar. 2013;25(3):190-6. [pmid: 23257248].
Nyarangi-Dix JN, Radtke JP, Hadaschik B, et al. Impact of complete bladder neck preservation on urinary continence, quality of life and surgical margins after radical prostatectomy: a randomized, controlled, single blind trial. J Urol. Mar. 2013;189(3):891-8. Epub 2012 Sep 24. [pmid: 23017512].
Robinson JW, Donnelly BJ, Siever JE, et al. A randomized trial of external beam radiotherapy versus cryoablation in patients with localized prostate cancer: quality of life outcomes. Cancer. Oct. 15. 2009;115(20):4695-704. [pmid: 19691092].
Salonen AJ, Taari K, Ala-Opas M, et al. Advanced prostate cancer treated with intermittent or continuous androgen deprivation in the randomised FinnProstate Study VII: quality of life and adverse effects. Eur Urol. Jan. 2013;63(1):111-20. [pmid: 22857983].
Schweizer MT, Huang P, Kattan MW, et al. Adjuvant leuprolide with or without docetaxel in patients with high-risk prostate cancer after radical prostatectomy (TAX-3501): Important lessons for future trials. Cancer. 2013;119(20):3610-8. [pmid: 23943299].
Taneja SS. Re: Dutasteride treatment over 2 years delays prostate-specific antigen progression in patients with biochemical failure after radical therapy for prostate cancer: Results from the randomised, placebo-controlled avodart after radical therapy for prostate cancer study (ARTS): Editorial comment. J Urol. 2013;189(5):1716. [pmid: 23594629].
Tombal B, Miller K, Boccon-Gibod L, et al. Additional analysis of the secondary end point of biochemical recurrence rate in a phase 3 trial (CS21) comparing degarelix 80 mg versus leuprolide in prostate cancer patients segmented by baseline characteristics. Eur Urol. May. 2010;57(5):836-42. [pmid: 19962227].
Warde P, Mason M, Ding K, et al. Combined androgen deprivation therapy and radiation therapy for locally advanced prostate cancer: a randomised, phase 3 trial. Lancet. Dec. 17. 2011;378(9809):2104-11. [pmid: 22056152].
Widmark A, Klepp O, Solberg A, et al. Endocrine treatment, with or without radiotherapy, in locally advanced prostate cancer (SPCG-7/SFUO-3): an open randomised phase III trial. Lancet. Jan. 24. 2009;373(9660):301-8. [pmid: 19091394].

## No outcomes of interest

Bellardita L, Rancati T, Valdagni R. Editorial Comment to health-related quality of life after carbon-ion radiotherapy for prostate cancer: A 3-year prospective study. Int J Urol. Apr. 2014;21(4):375-6. Epub 2013 Nov 13. [pmid: 24224716].
Black PC, Basen-Engquist K, Wang X, et al. A randomized prospective trial evaluating testosterone, haemoglobin kinetics and quality of life, during and after 12 months of androgen deprivation after prostatectomy: results from the Postoperative Adjuvant Androgen Deprivation trial. BJU Int. Jul. 2007;100(1):63-9. [pmid: 17552954].
Bratt O, Carlsson S, Holmberg E, et al. The Study of Active Monitoring in Sweden (SAMS): a randomized study comparing two different follow-up schedules for active surveillance of low-risk prostate cancer. Scand J Urol. Oct. 2013;47(5):347-55. [pmid: 23883427].
Chira C, Delouya G, Gruszczynski N, et al. Deferred permanent prostate seed brachytherapy does not affect PSA outcome: results from a large retrospective cohort. Can J Urol. Dec. 2013;20(6):7028-34. [pmid: 24331344].
de la Taille A. Comment on “Secondary chemoprevention of localized prostate cancer by short-term androgen deprivation to select indolent tumors suitable for active surveillance: a prospective pilot study”. World J Urol. 2014. Jan. 11. Epub ahead of print. [pmid: 24413818].
de Oliveira C, Bremner KE, Ni A, et al. Patient time and out-of-pocket costs for long-term prostate cancer survivors in Ontario, Canada. J Cancer Surviv. Mar. 2014;8(1):9-20. Epub 2013 Aug 23. [pmid: 23975612].
Hansen J, Gandaglia G, Bianchi M, et al. Re-assessment of 30-, 60- and 90-day mortality rates in non-metastatic prostate cancer patients treated either with radical prostatectomy or radiation therapy. Can Urol Assoc J. Jan. 2014;8(1-2):E75-80. [pmid: 24554978].
Hayes JH, Ollendorf DA, Pearson SD, et al. Observation versus initial treatment for men with localized, low-risk prostate cancer: a cost-effectiveness analysis. (Provisional abstract). Ann Intern Med. 2013;158(12):853-60. [pmid: 23778902].
Hernandez V, Blazquez C, de la Pena E, et al. Active surveillance in low-risk prostate cancer. Patient acceptance and results. Actas Urol Esp. Oct. 2013;37(9):533-7. Epub 2013 Apr 22. [pmid: 23618513].
Ko EC, Liu JT, Stone NN, et al. Association of early PSA failure time with increased distant metastasis and decreased survival in prostate brachytherapy patients. Radiother Oncol. Feb. 2014;110(2):261-7. Epub 2013. [pmid: 24299969].
Mostaghel EA, Nelson PS, Lange P, et al. Targeted androgen pathway suppression in localized prostate cancer: a pilot study. J Clin Oncol. Jan. 20. 2014;32(3):229-37. [pmid: 24323034].
Norkus D, Karklelyte A, Engels B, et al. A randomized hypofractionation dose escalation trial for high risk prostate cancer patients: interim analysis of acute toxicity and quality of life in 124 patients. Radiat Oncol. 2013;8(1):206. [pmid: 24007322].
Paiva CS, Andreoni C, Cunha GP, et al. Differences among patients undergoing perineal or retropubic radical prostatectomy in pain and perioperative variables: a prospective study. BJU Int. Nov. 2009;104(9):1219-26. [pmid: 19389007].
Parnes HL, Brawley OW, Minasian LM, et al. Phase III prostate cancer chemoprevention trials. Recent Results Cancer Res. 2014;202:73-7. [pmid: 24531780].
Reed DR, Wallner KE, Merrick GS, et al. A prospective randomized comparison of stranded vs. loose 125I seeds for prostate brachytherapy. Brachytherapy. Apr-Jun. 2007;6(2):129-34. [pmid: 17434106].
Sugihara T, Yasunaga H, Horiguchi H, et al. Comparisons of perioperative outcomes and costs between open and laparoscopic radical prostatectomy: a propensity-score matching analysis based on the Japanese Diagnosis Procedure Combination database. Int J Urol. Mar. 2013;20(3):349-53. [pmid: 23320826].
Sun L, Zhu X, Xu L, et al. Antitumor effects of (32)P-chromic-poly (L-lactide) brachytherapy in nude mice with human prostate cancer. Oncol Lett. Sep. 2013;6(3):687-92. [pmid: 24137391].
Vickers AJ, Thompson IM, Klein E, et al. A commentary on PSA velocity and doubling time for clinical decisions in prostate cancer. Urology. Mar. 2014;83(3):592-8. [pmid: 24581521].
Zumsteg ZS, Spratt DE, Pei I, et al. A new risk classification system for therapeutic decision making with intermediate-risk prostate cancer patients undergoing dose-escalated external-beam radiation therapy. Eur Urol. Dec. 2013;64(6):895-902. Epub 2013 Mar 23. [pmid: 23541457].

## No comparison of interest

Cronin-Fenton DP, Antonsen S, Cetin K, et al. Methods and rationale used in a matched cohort study of the incidence of new primary cancers following prostate cancer. Clin Epidemiol. 2013;5:429-37. [pmid: 24204172].
Crook JM. Intermittent and continuous androgen deprivation did not differ for mortality after radiotherapy for prostate CA. Ann Intern Med. 2013;158(2):JC9.
Davis JW, Chang DW, Chevray P, et al. Randomized phase II trial evaluation of erectile function after attempted unilateral cavernous nerve-sparing retropubic radical prostatectomy with versus without unilateral sural nerve grafting for clinically localized prostate cancer. Eur Urol. May. 2009;55(5):1135-43. [pmid: 18783876].
Dearnaley DP, Jovic G, Syndikus I, et al. Escalated-dose versus control-dose conformal radiotherapy for prostate cancer: long-term results from the MRC RT01 randomised controlled trial. Lancet Oncol. Apr. 2014;15(4):464-73. Epub 2014 Feb 26. [pmid: 24581940].
Dearnaley DP, Sydes MR, Graham JD, et al. Escalated-dose versus standard-dose conformal radiotherapy in prostate cancer: first results from the MRC RT01 randomised controlled trial. Lancet Oncol. Jun. 2007;8(6):475-87. [pmid: 17482880].
Dearnaley DP, Sydes MR, Langley RE, et al. The early toxicity of escalated versus standard dose conformal radiotherapy with neo-adjuvant androgen suppression for patients with localised prostate cancer: results from the MRC RT01 trial (ISRCTN47772397). Radiother Oncol. Apr. 2007;83(1):31-41. [pmid: 17391791].
Jia Z, Lilly MB, Koziol JA, et al. Generation of “virtual” control groups for single arm prostate cancer adjuvant trials. PLoS ONE. Jan. 21. 2014;9(1):e85010. [pmid: 24465467].
Kaushik D, Karnes RJ, Eisenberg MS, et al. Effect of metformin on prostate cancer outcomes after radical prostatectomy. Urol Oncol. Jan. 2014;32(1):43.e1-7. Epub 2013 Jun 28. [pmid: 23810664].
Keizman D, Zahurak M, Sinibaldi V, et al. Lenalidomide in nonmetastatic biochemically relapsed prostate cancer: results of a phase I/II double-blinded, randomized study. Clin Cancer Res. Nov. 1. 2010;16(21):5269-76. [pmid: 20978144].
Kellokumpu-Lehtinen PL, Hjälm-Eriksson M, Thellenberg-Karlsson C, et al. Toxicity in patients receiving adjuvant docetaxel + hormonal treatment after radical radiotherapy for intermediate or high-risk prostate cancer: a preplanned safety report of the SPCG-13 trial. Prostate Cancer Prostatic Dis. Sep. 2012;15(3):303-7. [pmid: 22546837].
Lista F, Gimbernat H, Caceres F, et al. Multiparametric magnetic resonance imaging for the assessment of extracapsular invasion and other staging parameters in patients with prostate cancer candidates for radical prostatectomy. Actas Urol Esp. Jun. 2014;38(5):290-7. Epub 2014 Jan 1. [pmid: 24387827].
Mathieu R, Arango JD, Beckendorf V, et al. Nomograms to predict late urinary toxicity after prostate cancer radiotherapy. World J Urol. Jun. 2014;32(3):743-51. Epub 2013 Aug 29. [pmid: 23990073].
Mitsuzuka K, Koie T, Narita S, et al. Is pelvic lymph node dissection required at radical prostatectomy for low-risk prostate cancer. Int J Urol. Nov. 2013;20(11):1092-6. Epub 2013 Feb 6. [pmid: 23387553].
Morris WJ, Spadinger I, Keyes M, et al. Whole prostate D90 and V100: a dose-response analysis of 2000 consecutive (125)I monotherapy patients. Brachytherapy. Jan-Feb. 2014;13(1):32-41. [pmid: 24126102].
Nobes JP, Langley SE, Klopper T, et al. A prospective, randomized pilot study evaluating the effects of metformin and lifestyle intervention on patients with prostate cancer receiving androgen deprivation therapy. BJU Int. May. 2012;109(10):1495-502. [pmid: 21933330].
Pokala N, Trulson JJ, Islam M. Long-term outcome following radical prostatectomy for Gleason 8-10 prostatic adenocarcinoma. World J Urol. 2014. Feb. 9. Epub ahead of print. [pmid: 24510158].
Reeve BB, Chen RC, Moore DT, Deal Ms AM, Usinger DS, Lyons JC, Talcott JA. Impact of comorbidity on health-related quality of life after prostate cancer treatment: combined analysis of two prospective cohort studies. BJU Int. 2014. Mar. 3. Epub ahead of print. Also available:http://dx.doi.org/10.1111/bju.12723. [pmid: 24588845].
Roder MA, Thomsen FB, Berg KD, et al. Risk of biochemical recurrence and positive surgical margins in patients with pT2 prostate cancer undergoing radical prostatectomy. J Surg Oncol. Feb. 2014;109(2):132-8. [pmid: 24155174].
Sfoungaristos S, Kontogiannis S, Perimenis P. Early continence recovery after preservation of maximal urethral length until the level of verumontanum during radical prostatectomy: Primary oncological and functional outcomes after 1 year of follow-up. Biomed Res Int. 2013. Epub ahead of print.
Sjoberg C, Lundmark M, Granberg C, et al. Clinical evaluation of multi-atlas based segmentation of lymph node regions in head and neck and prostate cancer patients. Radiat Oncol. 2013;8(1):229. [pmid: 24090107].
Sooriakumaran P, Coley HM, Fox SB, et al. A randomized controlled trial investigating the effects of celecoxib in patients with localized prostate cancer. Anticancer Res. May. 2009;29(5):1483-8. [pmid: 19443354].
Sundi D, Wang VM, Pierorazio PM, et al. Very-high-risk localized prostate cancer: definition and outcomes. Prostate Cancer Prostatic Dis. Mar. 2014;17(1):57-63. [pmid: 24189998].
Sutherland DE, Linder B, Guzman AM, et al. Posterior rhabdosphincter reconstruction during robotic assisted radical prostatectomy: results from a phase II randomized clinical trial. J Urol. Apr. 2011;185(4):1262-7. [pmid: 21334025].
Syndikus I, Morgan RC, Sydes MR, et al., MRC RT01 collaborators. Late gastrointestinal toxicity after dose-escalated conformal radiotherapy for early prostate cancer: results from the UK Medical Research Council RT01 trial (ISRCTN47772397). Int J Radiat Oncol Biol Phys. Jul. 1. 2010;77(3):773-83. [pmid: 19836155].
Taneja SS. Re: A phase 3, double-blind, randomised, parallel-group, placebo-controlled study of oral weekly alendronate for the prevention of androgen deprivation bone loss in nonmetastatic prostate cancer: The cancer and osteoporosis research with alendronate and leuprolide (CORAL) study: Editorial comment. J Urol. 2013;189(5):1714. [pmid: 23594627].
Thornqvist S, Hysing LB, Zolnay AG, et al. Adaptive radiotherapy in locally advanced prostate cancer using a statistical deformable motion model. Acta Oncol. Oct. 2013;52(7):1423-9. [pmid: 23964658].
Wang Y, Liu T, Rossi PJ, et al. Influence of vascular comorbidities and race on erectile dysfunction after prostate cancer radiotherapy. J Sex Med. Aug. 2013;10(8):2108-14. Epub 2013 Jun 6. [pmid: 23742221].
Werahera PN, Crawford ED, La Rosa FG, et al. Anterior tumors of the prostate: diagnosis and significance. Can J Urol. Oct. 2013;20(5):6897-906. [pmid: 24128826].
Woo SH, Kang DI, Ha YS, et al. Comprehensive analysis of sexual function outcome in prostate cancer patients after robot-assisted radical prostatectomy. J Endourol. Feb. 2014;28(2):172-7. [pmid: 23987521].

## Nonrandomized controlled trials with a mixed population (≥15% of patient population had T3 [not reporting T3a separately from T3b], T3b, or T4, or metastatic cancer and did not report separate data for T1 or T2 or T3a)

Albertsen PC, Klotz L, Tombal B, et al. Cardiovascular morbidity associated with gonadotropin releasing hormone agonists and an antagonist. Eur Urol. Mar. 2014;65(3):565-73. [pmid: 24210090].
Farioli A, Violante FS, Mattioli S, et al. Risk of mesothelioma following external beam radiotherapy for prostate cancer: a cohort analysis of SEER database. Cancer Causes Control. Aug. 2013;24(8):1535-45. [pmid: 23702885].
Gandaglia G, Karakiewicz PI, Briganti A, et al. Intensity-modulated radiation therapy leads to survival benefit only in patients with high-risk prostate cancer: a population-based study. Ann Oncol. May. 2014;25(2):979-86. Epub 2014 Feb 20. [pmid: 24562445].
Gandaglia G, Sun M, Hu JC, et al. Gonadotropin-releasing hormone agonists and acute kidney injury in patients with prostate cancer. Eur Urol. 2014. Jan. 28. Epub ahead of print. [pmid: 24495466].
Guttilla A, Bortolus R, Giannarini G, et al. Multimodal treatment for high-risk prostate cancer with high-dose intensity-modulated radiation therapy preceded or not by radical prostatectomy, concurrent intensified-dose docetaxel and long-term androgen deprivation therapy: results of a prospective phase II trial. Radiat Oncol. 2014;9:24. [pmid: 24423462].
Hoffman KE, Chen MH, Moran BJ, et al. Prostate cancer-specific mortality and the extent of therapy in healthy elderly men with high-risk prostate cancer. Cancer. Jun. 1. 2010;116(11):2590-5. [pmid: 20310055].
Hussain M, Tangen CM, Berry DL, et al. Intermittent versus continuous androgen deprivation in prostate cancer. N Engl J Med. Apr. 4. 2013;368(14):1314-25. [pmid: 23550669].
Kowalczyk KJ, Gu X, Nguyen PL, et al. Optimal timing of early versus delayed adjuvant radiotherapy following radical prostatectomy for locally advanced prostate cancer. Urol Oncol. Apr. 2014;32(3):303-8. Epub 2013 Dec 8. [pmid: 24321259].
Kyrdalen AE, Dahl AA, Hernes E, et al. A national study of adverse effects and global quality of life among candidates for curative treatment for prostate cancer. BJU Int. Feb. 2013;111(2):221-32. [pmid: 22672151].
Lawton CA, Bae K, Pilepich M, et al. Long-term treatment sequelae after external beam irradiation with or without hormonal manipulation for adenocarcinoma of the prostate: analysis of radiation therapy oncology group studies 85-31, 86-10, and 92-02. Int J Radiat Oncol Biol Phys. Feb. 1. 2008;70(2):437-41. [pmid: 17881145].
McBride D. New radiation therapy prolongs metastatic prostate cancer survival. ONS Connect. Sep. 2013;28(3):49. [pmid: 24028051].
Merino T, San Francisco IF, Rojas PA, et al. Intensity-modulated radiotherapy versus radical prostatectomy in patients with localized prostate cancer: long-term follow-up. BMC Cancer. 2013;13:530. [pmid: 24209381].
Schroder F, Bangma C, Angulo JC, et al. Dutasteride treatment over 2 years delays prostate-specific antigen progression in patients with biochemical failure after radical therapy for prostate cancer: results from the randomised, placebo-controlled Avodart after Radical Therapy for Prostate Cancer Study (ARTS). Eur Urol. 2013;63(5):779-87. [pmid: 23176897].
Studer UE, Whelan P, Wimpissinger F, et al. EORTC Genitourinary Cancer Group. Differences in time to disease progression do not predict for cancer-specific survival in patients receiving immediate or deferred androgen-deprivation therapy for prostate cancer: Final results of EORTC Randomized Trial 30891 with 12 years of follow-up. Eur Urol. 2013. Jul. 24. Epub ahead of print. [pmid: 23932338].
Sveistrup J, af Rosenschold PM, Deasy JO, et al. Improvement in toxicity in high risk prostate cancer patients treated with image-guided intensity-modulated radiotherapy compared to 3D conformal radiotherapy without daily image guidance. Radiat Oncol. 2014;9:44. [pmid: 24495815].
Thompson JE, Egger S, Bohm M, et al. Superior quality of life and improved surgical margins are achievable with robotic radical prostatectomy after a long learning curve: a prospective single-surgeon study of 1552 consecutive cases. Eur Urol. Mar. 2014;65(3):521-31. [pmid: 24287319].
Wenisch JM, Mayr FB, Spiel AO, et al. Androgen deprivation decreases prostate specific antigen in the absence of tumor: implications for interpretation of PSA results. Clin Chem Lab Med. Mar. 1. 2014;52(3):431-6. [pmid: 24423580].
Zwahlen DR, Andrianopoulos N, Matheson B, et al. High-dose-rate brachytherapy in combination with conformal external beam radiotherapy in the treatment of prostate cancer. Brachytherapy. Jan-Mar. 2010;9(1):27-35. [pmid: 19846348].

## Nonrandomized comparative studies without any attempt to control for selection bias using an acceptable method or <500 patients

Abdel-Wahab M, Reis IM, Hamilton K. Second primary cancer after radiotherapy for prostate cancer--a seer analysis of brachytherapy versus external beam radiotherapy. Int J Radiat Oncol Biol Phys. Sep. 1. 2008;72(1):58-68. [pmid: 18374503].
Abdollah F, Schmitges J, Sun M, et al. Comparison of mortality outcomes after radical prostatectomy versus radiotherapy in patients with localized prostate cancer: a population-based analysis. Int J Urol. Sep. 2012;19(9):836-44. [pmid: 22574746].
Abdollah F, Sun M, Schmitges J, et al. Survival benefit of radical prostatectomy in patients with localized prostate cancer: estimations of the number needed to treat according to tumor and patient characteristics. J Urol. Jul. 2012;188(1):73-83. [pmid: 22578732].
Abdollah F, Sun M, Thuret R, et al. A competing-risks analysis of survival after alternative treatment modalities for prostate cancer patients: 1988-2006. Eur Urol. Jan. 2011;59(1):88-95. [pmid: 20965646].
Aizer AA, Yu JB, Colberg JW, et al. Radical prostatectomy vs. intensity-modulated radiation therapy in the management of localized prostate adenocarcinoma. Radiother Oncol. Nov. 2009;93(2):185-91. [pmid: 19800702].
Akita H, Okamura T, Ando R, et al. Implications of greater short-term PSA recurrence with laparoscopic as compared to retropubic radical prostatectomy for Japanese clinically localized prostate carcinomas. Asian Pac J Cancer Prev. 2011;12(11):2959-61. [pmid: 22393971].
Albers P, Schafers S, Lohmer H, et al. Seminal vesicle-sparing perineal radical prostatectomy improves early functional results in patients with low-risk prostate cancer. BJU Int. Nov. 2007;100(5):1050-4. [pmid: 17760889].
Alibhai SM, Leach M, Warde P. Major 30-day complications after radical radiotherapy: a population-based analysis and comparison with surgery. Cancer. Jan. 15. 2009;115(2):293-302. [pmid: 19025976].
Arvold ND, Chen MH, Moul JW, et al. Risk of death from prostate cancer after radical prostatectomy or brachytherapy in men with low or intermediate risk disease. J Urol. Jul. 2011;186(1):91-6. [pmid: 21571341].
Bhojani N, Capitanio U, Suardi N, et al. The rate of secondary malignancies after radical prostatectomy versus external beam radiation therapy for localized prostate cancer: a population-based study on 17,845 patients. Int J Radiat Oncol Biol Phys. Feb. 1. 2010;76(2):342-48. [pmid: 20117287].
Bittner N, Merrick GS, Galbreath RW, et al. Primary causes of death after permanent prostate brachytherapy. Int J Radiat Oncol Biol Phys. Oct. 1. 2008;72(2):433-40. [pmid: 18448268].
Carlsson S, Nilsson AE, Schumacher MC, et al. Surgery-related complications in 1253 robot-assisted and 485 open retropubic radical prostatectomies at the Karolinska University Hospital, Sweden. Urology. May. 2010;75(5):1092-7. [pmid: 20022085].
Colberg JW, Decker RH, Khan AM, et al. Surgery versus implant for early prostate cancer: results from a single institution, 1992-2005. Cancer J. Jul-Aug. 2007;13(4):229-32. [pmid: 17762756].
Crook JM, Gomez-Iturriaga A, Wallace K, et al. Comparison of health-related quality of life 5 years after SPIRIT: Surgical Prostatectomy Versus Interstitial Radiation Intervention Trial. J Clin Oncol. Feb. 1. 2011;29(4):362-8. [pmid: 21149658].
Davison BJ, Matthew A, Gardner AM. Prospective comparison of the impact of robotic-assisted laparoscopic radical prostatectomy versus open radical prostatectomy on health-related quality of life and decision regret. Can Urol Assoc J. Jan. 2014;8(1-2):E68-72. [pmid: 24454607].
Deutsch I, Zelefsky MJ, Zhang Z, et al. Comparison of PSA relapse-free survival in patients treated with ultra-high-dose IMRT versus combination HDR brachytherapy and IMRT. Brachytherapy. Oct-Dec. 2010;9(4):313-8. [pmid: 20685176].
Elliott SP, Meng MV, Elkin EP, et al. Incidence of urethral stricture after primary treatment for prostate cancer: data From CaPSURE. J Urol. Aug. 2007;178(2):529-34. discussion 534. [pmid: 17570425].
Fitzsimons NJ, Sun LL, Dahm P, et al. A single-institution comparison between radical perineal and radical retropubic prostatectomy on perioperative and pathological outcomes for obese men: an analysis of the Duke Prostate Center database. Urology. Dec. 2007;70(6):1146-51. [pmid: 18158036].
Forsythe K, Blacksburg S, Stone N, et al. Intensity-modulated radiotherapy causes fewer side effects than three-dimensional conformal radiotherapy when used in combination with brachytherapy for the treatment of prostate cancer. Int J Radiat Oncol Biol Phys. Jun. 1. 2012;83(2):630-5. [pmid: 22099032].
Gacci M, Lapini A, Serni S, et al. Predictors of quality of life after radical treatment for prostate cancer. Urol Int. 2008;80(3):231-6. [pmid: 18480622].
Gillitzer R, Thomas C, Wiesner C, et al. Single center comparison of anastomotic strictures after radical perineal and radical retropubic prostatectomy. Urology. Aug. 2010;76(2):417-22. [pmid: 19969328].
Goldner G, Potter R, Battermann JJ, et al. Comparison between external beam radiotherapy (70 Gy/74 Gy) and permanent interstitial brachytherapy in 890 intermediate risk prostate cancer patients. Radiother Oncol. May. 2012;103(2):223-7. [pmid: 22398311].
Gonzalez-San Segundo C, Herranz-Amo F, Alvarez-Gonzalez A, et al. Radical prostatectomy versus external-beam radiotherapy for localized prostate cancer: long-term effect on biochemical control-in search of the optimal treatment. Ann Surg Oncol. Oct. 2011;18(10):2980-7. [pmid: 21431406].
Ho AY, Burri RJ, Cesaretti JA, et al. Radiation dose predicts for biochemical control in intermediate-risk prostate cancer patients treated with low-dose-rate brachytherapy. Int J Radiat Oncol Biol Phys. Sep. 1. 2009;75(1):16-22. [pmid: 19289266].
Hoppe BS, Michalski JM, Mendenhall NP, et al. Comparative effectiveness study of patient-reported outcomes after proton therapy or intensity-modulated radiotherapy for prostate cancer. Cancer. Apr. 1. 2014;120(7):1076-82. Epub 2013 Dec 30. [pmid: 24382757].
Hu JC, Gu X, Lipsitz SR, et al. Comparative effectiveness of minimally invasive vs open radical prostatectomy. JAMA. Oct. 14. 2009;302(14):1557-64. [pmid: 19826025].
Huang GJ, Sadetsky N, Penson DF. Health related quality of life for men treated for localized prostate cancer with long-term followup. J Urol. Jun. 2010;183(6):2206-12. [pmid: 20399462].
Huang J, Kestin LL, Ye H, et al. Analysis of second malignancies after modern radiotherapy versus prostatectomy for localized prostate cancer. Radiother Oncol. Jan. 2011;98(1):81-6. [pmid: 20951450].
Jacobs BL, Zhang Y, Skolarus TA, et al. Comparative effectiveness of external-beam radiation approaches for prostate cancer. Eur Urol. Jan. 2014;65(1):162-8. Epub 2012 Jul 6. [pmid: 22790288].
Jeldres C, Suardi N, Perrotte P, et al. Survival after radical prostatectomy and radiotherapy for prostate cancer: a population-based study. Can Urol Assoc J. Feb. 2009;3(1):13-21. [pmid: 19293970].
Kasperzyk JL, Shappley WV 3rd, Kenfield SA, et al. Watchful waiting and quality of life among prostate cancer survivors in the Physicians' Health Study. J Urol. Nov. 2011;186(5):1862-7. [pmid: 21944095].
Keating NL, O'Malley AJ, Freedland SJ, et al. Diabetes and cardiovascular disease during androgen deprivation therapy: observational study of veterans with prostate cancer. J Natl Cancer Inst. Jan. 6. 2010;102(1):39-46. [pmid: 19996060].
Khor R, Duchesne G, Tai KH, et al. Direct 2-arm comparison shows benefit of high-dose-rate brachytherapy boost vs external beam radiation therapy alone for prostate cancer. Int J Radiat Oncol Biol Phys. 2012. Sep. 3. [pmid: 22954770].
Kim SC, Song C, Kim W, et al. Factors determining functional outcomes after radical prostatectomy: robot-assisted versus retropubic. Eur Urol. Sep. 2011;60(3):413-9. [pmid: 21612859].
Kluth LA, Abdolllah F, Xylinas E, et al. Pathologic nodal staging scores in patients treated with radical prostatectomy: a postoperative decision tool. Eur Urol. 2013. Jul. 2. Epub ahead of print. [pmid: 23850255].
Kordan Y, Barocas DA, Altamar HO, et al. Comparison of transfusion requirements between open and robotic-assisted laparoscopic radical prostatectomy. BJU Int. Oct. 2010;106(7):1036-40. [pmid: 20151960].
Kowalczyk KJ, Levy JM, Caplan CF, et al. Temporal national trends of minimally invasive and retropubic radical prostatectomy outcomes from 2003 to 2007: results from the 100% Medicare sample. Eur Urol. Apr. 2012;61(4):803-9. [pmid: 22209053].
Ladjevardi S, Sandblom G, Berglund A, et al. Tumour grade, treatment, and relative survival in a population-based cohort of men with potentially curable prostate cancer. Eur Urol. Apr. 2010;57(4):631-8. [pmid: 19299069].
Liu L, Coker AL, Du XL, et al. Long-term survival after radical prostatectomy compared to other treatments in older men with local/regional prostate cancer. J Surg Oncol. Jun. 1. 2008;97(7):583-91. [pmid: 18381603].
Lowrance WT, Elkin EB, Jacks LM, et al. Comparative effectiveness of prostate cancer surgical treatments: a population based analysis of postoperative outcomes. J Urol. Apr. 2010;183(4):1366-72. [pmid: 20188381].
Lughezzani G, Sun M, Perrotte P, et al. Comparative study of inguinal hernia repair rates after radical prostatectomy or external beam radiotherapy. Int J Radiat Oncol Biol Phys. Dec. 1. 2010;78(5):1307-13. [pmid: 20381269].
Margel D, Baniel J, Wasserberg N, et al. Radiation therapy for prostate cancer increases the risk of subsequent rectal cancer. Ann Surg. Dec. 2011;254(6):947-50. [pmid: 22107741].
Martinschek A, Heinzelmann K, Ritter M, et al. Radical prostatectomy after previous transurethral resection of the prostate: robot-assisted laparoscopic versus open radical prostatectomy in a matched-pair analysis. J Endourol. Sep. 2012;26(9):1136-41. [pmid: 22489895].
May M, Dorst M, May J, et al. Radical retropubic vs. radical perineal prostatectomy: a comparison of relative benefits in four urban hospitals. Urol Nurs. Dec. 2007;27(6):519-26. [pmid: 18217535].
Merglen A, Schmidlin F, Fioretta G, et al. Short- and long-term mortality with localized prostate cancer. Arch Intern Med. Oct. 8. 2007;167(18):1944-50. [pmid: 17923593].
Miwa S, Mizokami A, Konaka H, et al. Prospective longitudinal comparative study of health-related quality of life and treatment satisfaction in patients treated with hormone therapy, radical retropubic prostatectomy, and high or low dose rate brachytherapy for prostate cancer. Prostate Int. 2013;1(3):117-24. [pmid: 24223413].
Mullins JK, Feng Z, Trock BJ, et al. The impact of anatomical radical retropubic prostatectomy on cancer control: the 30-year anniversary. J Urol. Dec. 2012;188(6):2219-24. [pmid: 23083655].
Muramaki M, Miyake H, Behnsawy HM, et al. Assessment of postoperative quality of life: comparative study between laparoscopic and minimum incision endoscopic radical prostatectomies. Int J Clin Oncol. 2013. Dec. 27. Epub ahead of print. [pmid: 24370729].
Nam RK, Cheung P, Herschorn S, et al. Incidence of complications other than urinary incontinence or erectile dysfunction after radical prostatectomy or radiotherapy for prostate cancer: a population-based cohort study. Lancet Oncol. Feb. 2014;15(2):223-31. [pmid: 24440474].
Namiki S, Kwan L, Kagawa-Singer M, et al. Distress and social dysfunction following prostate cancer treatment: a longitudinal cross-cultural comparison of Japanese and American men. Prostate Cancer Prostatic Dis. 2009;12(1):67-71. [pmid: 18392046].
Nieder AM, Porter MP, Soloway MS. Radiation therapy for prostate cancer increases subsequent risk of bladder and rectal cancer: a population based cohort study. J Urol. Nov. 2008;180(5):2005-9. discussion 2009-1. [pmid: 18801517].
Penson DF. Commentary on: Quality of life after surgery, external beam irradiation, or brachytherapy for early-stage prostate cancer. Urol Oncol. Sep/Oct. 2007;25(5):442-43.
Pickles T, Keyes M, Morris WJ. Brachytherapy or conformal external radiotherapy for prostate cancer: a single-institution matched-pair analysis. Int J Radiat Oncol Biol Phys. Jan. 1. 2010;76(1):43-9. [pmid: 19570619].
Pickles T, Morris WJ, Kattan MW, et al. Comparative 5-year outcomes of brachytherapy and surgery for prostate cancer. Brachytherapy. Jan-Feb. 2011;10(1):9-14. [pmid: 20605535].
Prasad SM, Gu X, Lavelle R, et al. Comparative effectiveness of perineal versus retropubic and minimally invasive radical prostatectomy. J Urol. Jan. 2011;185(1):111-5. [pmid: 21074198].
Rice KR, Colombo ML, Wingate J, et al. Low risk prostate cancer in men ≥70 years old: To treat or not to treat. Urol Oncol. 2011. Aug. 25. [pmid: 21872499].
Ryu J, Kwon T, Kyung YS, et al. Retropubic versus robot-assisted laparoscopic prostatectomy for prostate cancer: a comparative study of postoperative complications. Korean J Urol. Nov. 2013;54(11):756-61. [pmid: 24255757].
Schymura MJ, Kahn AR, German RR, et al. Factors associated with initial treatment and survival for clinically localized prostate cancer: results from the CDC-NPCR Patterns of Care Study (PoC1). BMC Cancer. 2010;10:152. [pmid: 20403178].
Shah C, Lanni TB, Ghilezan MI, et al. Brachytherapy provides comparable outcomes and improved cost-effectiveness in the treatment of low/intermediate prostate cancer. Brachytherapy. Nov. 2012;11(6):441-45. [pmid: 22728157].
Shapiro EY, Rais-Bahrami S, Morgenstern C, et al. Long-term outcomes in younger men following permanent prostate brachytherapy. J Urol. Apr. 2009;181(4):1665-71. discussion 1671. [pmid: 19233394].
Shen X, Keith SW, Mishra MV, et al. The impact of brachytherapy on prostate cancer-specific mortality for definitive radiation therapy of high-grade prostate cancer: a population-based analysis. Int J Radiat Oncol Biol Phys. Jul. 15. 2012;83(4):1154-9. [pmid: 22270175].
Shih YC, Ward JF, Pettaway CA, et al. Comparative effectiveness, cost, and utilization of radical prostatectomy among young men within managed care insurance plans. Value Health. Mar-Apr. 2012;15(2):367-75. [pmid: 22433769].
Shilkrut M, Merrick GS, McLaughlin PW, et al. The addition of low-dose-rate brachytherapy and androgen-deprivation therapy decreases biochemical failure and prostate cancer death compared with dose-escalated external-beam radiation therapy for high-risk prostate cancer. Cancer. Feb. 1. 2013;119(3):681-90. [pmid: 22893254].
Stranne J, Johansson E, Nilsson A, et al. Inguinal hernia after radical prostatectomy for prostate cancer: results from a randomized setting and a nonrandomized setting. Eur Urol. Nov. 2010;58(5):719-26. [pmid: 20728265].
Tai P, Tonita J, Woitas C, et al. Treatment outcomes in non-metastatic prostate cancer patients with ultra-high prostate-specific antigen. Int J Radiat Oncol Biol Phys. Jul. 15. 2012;83(4):e525-30. [pmid: 22483701].
Talcott JA, Manola J, Chen RC, et al. Using patient-reported outcomes to assess and improve prostate cancer brachytherapy. BJU Int. 2013. Sep. 20. Epub ahead of print. [pmid: 24112602].
Touijer K, Eastham JA, Secin FP, et al. Comprehensive prospective comparative analysis of outcomes between open and laparoscopic radical prostatectomy conducted in 2003 to 2005. J Urol. May. 2008;179(5):1811-7. discussion 1817. [pmid: 18353387].
Trinh QD, Sammon J, Sun M, et al. Perioperative outcomes of robot-assisted radical prostatectomy compared with open radical prostatectomy: results from the nationwide inpatient sample. Eur Urol. Apr. 2012;61(4):679-85. [pmid: 22206800].
Van Velthoven R, Aoun F, Limani K, et al. Primary zonal high intensity focused ultrasound for prostate cancer: results of a prospective phase IIa feasibility study. Prostate Cancer. 2014;2014:756189. [pmid: 24587908].
Westover K, Chen MH, Moul J, et al. Radical prostatectomy vs radiation therapy and androgen-suppression therapy in high-risk prostate cancer. BJU Int. Oct. 2012;110(8):1116-21. [pmid: 22540922].
Williams S, Buyyounouski M, Kestin L, et al. Predictors of androgen deprivation therapy efficacy combined with prostatic irradiation: the central role of tumor stage and radiation dose. Int J Radiat Oncol Biol Phys. Mar. 1. 2011;79(3):724-31. [pmid: 20472361].
Williams SB, Prasad SM, Weinberg AC, et al. Trends in the care of radical prostatectomy in the United States from 2003 to 2006. BJU Int. Jul. 2011;108(1):49-55. [pmid: 21087390].
Yu JB, Soulos PR, Herrin J, et al. Proton versus intensity-modulated radiotherapy for prostate cancer: patterns of care and early toxicity. J Natl Cancer Inst. Jan. 2. 2013;105(1):25-32. [pmid: 23243199].
Zelefsky MJ, Chou JF, Pei X, et al. Predicting biochemical tumor control after brachytherapy for clinically localized prostate cancer: The Memorial Sloan-Kettering Cancer Center experience. Brachytherapy. Jul-Aug. 2012;11(4):245-9. [pmid: 21925957].
Zelefsky MJ, Pei X, Teslova T, et al. Secondary cancers after intensity-modulated radiotherapy, brachytherapy and radical prostatectomy for the treatment of prostate cancer: incidence and cause-specific survival outcomes according to the initial treatment intervention. BJU Int. Dec. 2012;110(11):1696-701. [pmid: 22889401].
Zelefsky MJ, Yamada Y, Fuks Z, et al. Long-term results of conformal radiotherapy for prostate cancer: impact of dose escalation on biochemical tumor control and distant metastases-free survival outcomes. Int J Radiat Oncol Biol Phys. Jul. 15. 2008;71(4):1028-33. [pmid: 18280056].
Zelefsky MJ, Yamada Y, Pei X, et al. Comparison of tumor control and toxicity outcomes of high-dose intensity-modulated radiotherapy and brachytherapy for patients with favorable risk prostate cancer. Urology. Apr. 2011;77(4):986-90. [pmid: 21195465].
Zwahlen DR, Andrianopoulos N, Matheson B, et al. High-dose-rate brachytherapy in combination with conformal external beam radiotherapy in the treatment of prostate cancer. Brachytherapy. 2010 Jan/2010 Mar. 9(1):27-35. [pmid: 19846348].

## Studies that did not provide any information on provider characteristics, outcome of interest, or single center for KQ 3

Attalla K, Raza SJ, Rehman S, et al. Effectiveness of a dedicated robot-assisted surgery training program. Can J Urol. Dec. 2013;20(6):7084-90. [pmid: 24331355].
Baade PD, Youlden DR, Coory MD, et al. Urban-rural differences in prostate cancer outcomes in Australia: what has changed?. Med J Aust. Mar. 21. 2011;194(6):293-6. [pmid: 21426283].
Baumunk D, Reunkoff R, Kushner J, et al. Interdisciplinary decision making in prostate cancer therapy - 5-years' time trends at the Interdisciplinary Prostate Cancer Center (IPC) of the Charite Berlin. BMC Med Inform Decis Mak. 2013;13:83. [pmid: 23915212].
Beaulieu L, Evans DA, Aubin S, et al. Bypassing the learning curve in permanent seed implants using state-of-the-art technology. Int J Radiat Oncol Biol Phys. Jan. 1. 2007;67(1):71-7. [pmid: 16997500].
Briganti A, Bianchi M, Sun M, et al. Impact of the introduction of a robotic training programme on prostate cancer stage migration at a single tertiary referral centre. BJU Int. 2012. Nov. 13. [pmid: 23145532].
Choi WW, Gu X, Lipsitz SR, et al. The effect of minimally invasive and open radical prostatectomy surgeon volume. Urol Oncol. Sep. 2012;30(5):569-76. [pmid: 20822929].
Doumerc N, Yuen C, Savdie R, et al. Should experienced open prostatic surgeons convert to robotic surgery? The real learning curve for one surgeon over 3 years. BJU Int. Aug. 2010;106(3):378-84. [pmid: 20067454].
Eliya F, Kernen K, Gonzalez J, et al. Radical perineal prostatectomy: a learning curve. Int Urol Nephrol. Mar. 2011;43(1):139-42. [pmid: 20882343].
Evans SM, Millar JL, Frydenberg M, et al. Positive surgical margins: rate, contributing factors and impact on further treatment: findings from the Prostate Cancer Registry. BJU Int. 2013. Oct. 15. Epub ahead of print. [pmid: 24128010].
Hanchanale VS, Javle P. Impact of hospital provider volume on outcome for radical urological cancer surgery in England. Urol Int. 2010;85(1):11-5. [pmid: 20616525].
Hartz A, He T, Strope S, et al. Surgeon variation in patient quality of life following a radical prostatectomy. J Urol. 2012. Oct. 31. [pmid: 23123548].
Hashimoto T, Yoshioka K, Gondo T, et al. Learning curve and perioperative outcomes of robot-assisted radical prostatectomy in 200 initial Japanese cases by a single surgeon. J Endourol. Oct. 2013;27(10):1218-23. [pmid: 23834506].
Imamoto T, Goto Y, Utsumi T, et al. Complications, urinary continence, and oncologic outcomes of laparoscopic radical prostatectomy: single-surgeon experience for the first 100 cases. Prostate Cancer. 2011;2011:606505. Epub 2011 Jul 14. [pmid: 22110991].
Jang TL, Bekelman JE, Liu Y, et al. Physician visits prior to treatment for clinically localized prostate cancer. Arch Intern Med. Mar. 8. 2010;170(5):440-50. [pmid: 20212180].
Krahn MD, Bremner KE, Zagorski B, et al. Health care costs for state transition models in prostate cancer. Med Decis Making. Apr. 2014;34(3):366-78. Epub 2013 Jul 26. [pmid: 23894082].
Lebeau T, Roupret M, Ferhi K, et al. The role of a well-trained team on the early learning curve of robot-assisted laparoscopic procedures: the example of radical prostatectomy. Int J Med Robot. 2011. Oct. 7. [pmid: 22556136].
Oon SF, Cullen IM, Moran D, et al. The effect of a rapid access prostate cancer clinic on prostate cancer patient and disease characteristics, primary treatment and surgical workload. Ir J Med Sci. Jun. 2014;183(2):241-7. Epub 2013 Aug 8. [pmid: 23925926].
Pate SC, Uhlman MA, Rosenthal JA, et al. Variations in the open market costs for prostate cancer surgery: a survey of USA hospitals. Urology. Mar. 2014;83(3):626-31. [pmid: 24439795].
Philippou P, Waine E, Rowe E. Robot-assisted laparoscopic prostatectomy versus open: comparison of the learning curve of a single surgeon. J Endourol. Aug. 2012;26(8):1002-8. [pmid: 22390682].
Saito FJ, Dall'Oglio MF, Ebaid GX, et al. Learning curve for radical retropubic prostatectomy. Int Braz J Urol. Jan-Feb. 2011;37(1):67-74. discussion 75-8. [pmid: 21385482].
Schroeck FR, Kaufman SR, Jacobs BL, et al. Regional variation in quality of prostate cancer care. J Urol. Apr. 2014;191(4):957-62. Epub 2013 Oct 19. [pmid: 24144685].
Sheets NC, Hendrix LH, Allen IM, et al. Trends in the use of postprostatectomy therapies for patients with prostate cancer: a surveillance, epidemiology, and end results Medicare analysis. Cancer. Sep. 15. 2013;119(18):3295-301. Epub 2013 Jul 10. [pmid: 23842985].
Shimer SE. Prostate cancer treatment modalities and survival outcomes: a comparative analysis of falmouth hospital versus massachusetts and nationwide hospitals. J Registry Manag. 2013;40(2):78-83. [pmid: 24002132].
Sooriakumaran P, Srivastava A, Shariat SF, et al. A multinational, multi-institutional study comparing positive surgical margin rates among 22393 open, laparoscopic, and robot-assisted radical prostatectomy patients. Eur Urol. 2013. Nov. 24. Epub ahead of print. [pmid: 24290695].
Steinsvik EA, Axcrona K, Angelsen A, et al. Does a surgeon's annual radical prostatectomy volume predict the risk of positive surgical margins and urinary incontinence at one-year follow-up? Findings from a prospective national study. Scand J Urol. April. 2013;47(2):92-100. [pmid: 22860630].
Tol-Geerdink JJ, Willem Leer J, Weijerman PC, et al. Choice between prostatectomy and radiotherapy when men are eligible for both: A randomized controlled trial of usual care vs decision aid. BJU Int. 2013;111(4):564-73. [pmid: 22882966].
Ulmer WD, Prasad SM, Kowalczyk KJ, et al. Factors associated with the adoption of minimally invasive radical prostatectomy in the United States. J Urol. Sep. 2012;188(3):775-80. [pmid: 22818134].
Vickers A, Bianco F, Cronin A, et al. The learning curve for surgical margins after open radical prostatectomy: implications for margin status as an oncological end point. J Urol. Apr. 2010;183(4):1360-5. [pmid: 20171687].
Vickers AJ, Bianco FJ, Gonen M, et al. Effects of pathologic stage on the learning curve for radical prostatectomy: evidence that recurrence in organ-confined cancer is largely related to inadequate surgical technique. Eur Urol. May. 2008;53(5):960-6. [pmid: 18207316].
Vickers AJ, Bianco FJ, Serio AM, et al. The surgical learning curve for prostate cancer control after radical prostatectomy. J Natl Cancer Inst. Aug. 1. 2007;99(15):1171-7. [pmid: 17652279].
Vickers AJ, Cronin AM. Data and programming code from the studies on the learning curve for radical prostatectomy. BMC Res Notes. 2010;3:234. [pmid: 20813026].
Vickers AJ, Savage CJ, Hruza M, et al. The surgical learning curve for laparoscopic radical prostatectomy: a retrospective cohort study. Lancet Oncol. May. 2009;10(5):475-80. [pmid: 19342300].

## Duplicate

Porpiglia F, Morra I, Lucci Chiarissi M, et al. Randomized controlled trial comparing laparoscopic and robot-assisted radical prostatectomy. J Endourol. 2013;27(2):120-1.