# Acronyms and Abbreviations

3D-CRT: three-dimensional conformal radiotherapy
95% CI: 95 percent confidence interval
ADT: androgen deprivation therapy
AJCC: American Joint Committee on Cancer
AHRQ: Agency for Healthcare Research and Quality (U.S. Department of Health and Human Services)
ARR: absolute risk reduction
BT: brachytherapy
CAPRA: UCSF Cancer of the Prostate Risk Assessment
CT: computed tomography
DRE: digital rectal exam
EB-IGRT: external beam image-guided radiation therapy
EBRT: external beam radiation therapy
EORTC-QLQ: European Organization for Research and Treatment of Cancer Quality of Life Questionnaire
EPC: Evidence-based Practice Center
EPIC: Expanded Prostate Cancer Index Composite
ERSPC: European Randomized Study of Screening for Prostate Cancer
Gy: gray
HDR-EBRT: high dose–rate external beam radiation therapy
HDS: high dose rate
HIFU: high-intensity focused ultrasound
HR: hazard ratio
IGRT: image-guided radiation therapy
IMRT: intensity-modulated radiation therapy
IQR: interquartile range
KQ: Key Question
LDR: low dose rate
LHRH: luteinizing hormone–releasing hormone
LRP: laparoscopic radical prostatectomy
MRI: magnetic resonance imaging
NCCN: National Comprehensive Cancer Network
NIH: National Institutes of Health
OR: odds ratio
PCSM: prostate cancer–specific mortality
PICOTS: Population (patients), Intervention, Comparators, Outcomes, Timing, Setting
PIVOT: Prostate Cancer Intervention Versus Observation Trial
PLCO: Prostate, Lung, Colorectal, and Ovarian cancer screening trial
PSA: prostate-specific antigen
QOL: quality of life
RALRP: robotic-assisted laparoscopic radical prostatectomy
RARP: robot-assisted radical prostatectomy
RCT: randomized controlled trial
ROB: risk of bias
RP: radical prostatectomy
RPP: radical perineal prostatecto
RR: relative risk
RRP: radical retropubic prostatectomy
SEER: Surveillance Epidemiology and End Results (National Cancer Institute)
SF-36: Short Form-36
SOE: strength of evidence
SPCG-4: Scandinavian Prostate Cancer Group-4
TEP: Technical Expert Panel
TNM: T (tumor) N (lymph node) M (metastases) classification system (American Joint Committee on Cancer)
TOO: Task Order Officer
TRUS: transrectal ultrasound of the prostate
TURP: transurethral resection of the prostate
USPSTF: U.S. Preventive Services Task Force
WW: watchful waiting

Note: Acronyms and abbreviations used in appendix tables are defined within the tables in which they appear.