# Results

Figure 1 summarizes the literature identification process. Overall, 16,669 citations were screened, 516 were retrieved in full text and 87 were eligible. See Appendix E for a list of the included articles and Appendix F for a list of the articles excluded during full text review. Of the eligible studies, 88 articles, corresponding to 68 RCTs, pertained to the first Key Question,27-108 and 5 articles, corresponding to 5 studies, pertained to the second Key Question.109-113 One RCT addressed both Key Question 1^106^ and Key Question 2.^111^

Figure 1 Literature flow for the systematic review

Abbreviations: CENTRAL = Cochrane Central Register of Controlled Trials; CINAHL = Cumulative Index to Nursing and Allied Health Literature; ILL = inter-library-loan; KQ1, KQ2 = First, second Key Question; RCT= randomized controlled trial.

Figure 1 depicts the flow of literature from the total number of citations retrieved by database searching to the number excluded during abstract screening, then the number excluded by full text screening, and finally the total number of eligible citations for each Key Question. Overall, 15,515 citations were screened, 446 were retrieved in full text and 84 were eligible, including 81 citations eligible for Key Question 1 and 3 citations eligible for Key Question 2.

Extracted data are publicly available online at the Systematic Review Data Repository (http://srdr.ahrq.gov/projects/143, last accessed October 12, 2014).

## Comparative Effectiveness of Patient Decision Aids (Key Question 1)

Table 2 summarizes characteristics of the 68 eligible trials (25,337 enrolled patients). Most trials (65 out of 68) focused on decisions relevant to breast, prostate, or colorectal cancer. The other three topics pertained to thyroid, cervical, and ovarian cancer-related decisions. Thirty-seven (out of 68) studies were conducted in the USA, and 14 in Australia. Nine studies were cluster randomized trials. Thirty-eight studies were multi-center trials. Twenty and 24 studies were conducted in a primary care and specialized care setting, respectively, with 24 in other settings (e.g. over the internet) or not reported.

Table 2 Summary descriptives for included trials of decision aid interventions

Population Group | Average Risk of Cancer (Screening) | High Risk of Cancer (Screening or Treatment) | Early Cancer (Treatment)
Number of studies (people) | 33 (17,344) | 13 (3656) | 22 (5489)
Cancers considered (number of studies) | Breast (2), prostate (23), colorectal (8) | Breast (11), colorectal (1), ovarian (1) | Breast (9), prostate (10), colorectal (1), cervical (1), thyroid (1)
Mean participant age (median, range) | 59 (43, 70) | 44 (39, 62) | 59 (46, 72)
Sample size median (range) | 412 (49, 1960) | 153 (30, 1197) | 201 (60, 736)
Publication year (range) | 2000-2014 | 1997-2012 | 1995-2013
Studies conducted in the United States, number (%) | 22 (69%) | 7 (50%) | 9 (41%)
Studies with <50% participants completed high school, number (%) | 3 (9%) | 1 (7%) | 6 (27%)
Comparators, median (range) | 2 (2, 4) | 2 (2, 3) | 2 (2, 4)
Total number of trial arms with decision aid interventions | 52 | 18 | 23
Delivery formats, number (% out of decision aid arms)
Audio and visual media | 13 (25) | 0 (0) | 6 (26)
Software or Web site | 20 (38) | 7 (39) | 9 (39)
Printed material | 26 (50) | 7 (39) | 13 (57)
Option grid/decision board | 0 (0) | 1 (6) | 5 (22)
In-person education | 8 (15) | 10 (56) | 5 (22)
Content, number (% of decision 93 decision aid arms)
Explicit elicitation of values | 22 (42) | 7 (39) | 9 (39)
Generic risk probabilities | 34 (65) | 15 (83) | 11 (48)
Personalized risk probabilities | 7 (13) | 14 (78) | 4 (17)
Others' opinions | 27 (52) | 7 (39) | 12 (52)
Non-human-mediated guidance in decision making | 9 (17) | 4 (22) | 5 (22)
Human coaching in decision making | 8 (15) | 12 (67) | 9 (39)
Other attributes, number (% of decision aids)
Interactive | 24 (46) | 12 (67) | 16 (70)
Tailored to target population | 12 (23) | 1 (6) | 3 (13)
Used by consumer & provider | 4 (8) | 8 (44) | 4 (17)
Used by consumer only | 48 (92) | 10 (56) | 19 (83)

Most studies (n=33) assessed the effect of decision aids on screening-related decisions, 22 studies assessed treatment-related decisions and 13 studies assessed decisions pertaining to genetic risk. No trials were identified that examined decisions about malignancies in children. Appendix D, Table of Study Characteristics, displays the characteristics of each trial addressing Key Question 1.

In total, 55 distinct decision aids were examined in the 68 trials. Nine decision aids were examined in two trials (and two in three). In all cases when more than one trial evaluated a decision aid, the authors overlap, suggesting use of the aid by the same team. Usually, one or more decision aids were compared with usual care or no intervention, with the exception of eight studies where a head-to-head comparison between decision aids without another control group was implemented. The formats and contents of decision aids are summarized in Table 2.

Random sequence generation was clearly reported in 38 of the studies, and reporting was unclear in the remaining 30. Allocation of interventions was concealed in 32 studies, primarily through the use of a Web site where allocation was performed automatically. By design, masking of patients was impractical in most studies. Masking for outcome assessment would be feasible for outcomes that were not self-reported, but most studies did not explicitly report such information. Finally, attrition rates more than 20 percent were reported in 28 studies. Small attrition rates (<20%) were reported in seven studies, and the attrition was unclear in the remaining studies. However, it is not clear why the attrition rates would be associated with the intervention, or the outcome.

### Evolution of Formats and Contents of Decision Aid-Based Interventions Over Time

The 68 included trials (Table 2) were published over the last two decades (1995-2014). Figure 2 shows the evolution over time of the decision aid delivery formats used in the studies assessed in this systematic review. Over this period technologies, such as the Internet and personal computers, have evolved substantially and their availability has increased. The evolution of formats parallels the increasing penetration of technology in recent years. Internet-based decision aids have become more common, while use of printed materials, audio- and video- cassettes and compact discs, and in-person delivery of educational material by someone other than the provider have become less common.

Figure 2 Evolution of delivery formats over time

Notes: Shown are trial arms including decision aids, denoted by circles. Some trials have more than one decision aid arm. The bold red lines correspond to the percent of trial arms with a respective delivery format over time: An example to help in interpreting the plots: the use of audiotapes and videocassettes or CDs (“audio and visual media”) has declined, whereas the use of software- or Internet-based decision aids has increased.

Figure 2 depicts the change in decision aid formats over time. There is a separate subfigure for audio and visual media format, software or website format, printed material format, in-person education format, and option grid or decision board format. In each subfigure, there is a bold red line that corresponds to the change over time in the proportion of delivery aids using the format. Use of audio and visual media and printed material has declined over time, while use of software or Web sites has increased. Trends in in-person education and option grids or decision boards are unclear.

Figure 3 shows the corresponding evolution of the content-related attributes of decision aids for the included studies. Over recent years, explicit clarification of values has become more common. The proportion of decision aids presenting generic expected probabilities for outcomes has remained approximately constant, while the proportion presenting such probabilities as conditional on patient characteristics has diminished (some decision aids do not present outcome probabilities). The proportion of decision aids employing non-human-mediated guidance in decision making has increased in recent years, while human-mediated coaching in decision making has become less common.

Figure 3 Evolution of decision-aid content-related attributes over time

Notes: Coaching = human-mediated coaching in decision making; guidance = non-human-mediated guidance in decision making.

Figure 3 depicts the change in decision aid contents over time. There is a separate subfigure for explicit values clarification, generic probability of outcomes, personalized probability of outcomes, others' opinions, guidance, and coaching. In each subfigure, there is a bold red line that corresponds to the change over time in the proportion of delivery aids with the content. Personalized probability of outcomes and coaching have declined over time, while explicit values clarification has increased.

Figures 2 and 3 suggest that recent trials are increasingly studing decision aids that are more practical to deliver, e.g., over the Web or through computer software, without human mediation, and that they more often elicit preferences explicitly.

## Overview of Assessed Outcomes in the Included Studies

As shown in Figure 4, this literature has a proliferation of outcome measures, and few studies use similar outcome definitions, which hinders our ability to perform quantitative analyses. In the figure, filled or empty circles mark which of the 68 trials (rows) reported results on 15 prespecified outcome categories (columns). In three outcome categories (knowledge about condition and options; decisional conflict; and anxiety, depression, worry), black markers denote that the corresponding trials results have been included in a quantitative synthesis. All other trial results (empty circles) are synthesized only qualitatively. Although for some outcome categories many trials provide information, they use very different outcome definitions (e.g. anxiety, depression and worry scales used to assess the effect of a decision aid) not allowing a quantitative synthesis.

Figure 4 Overview of outcome categories reported in the eligible trials

Notes: Each row corresponds to a trial. Two horizontal thick black lines separate trials in populations at average risk for cancer (top), high risk for cancer (middle), and with early cancer (bottom). The 15 columns correspond to predefined outcome categories, in the order they are described in the text. Three vertical black thick lines separate outcomes related to measurements of decisional quality and cognition, attributes of the decision-making process; affect, emotion, and quality of life; and process and system-level outcomes. An empty cell means that a study (row) did not report on an outcome (column). A cell with an empty marker means that a study reported a result, but that no meta-analysis was done. In three columns, cells with filled black circles correspond to trials include in a quantitative analysis.

Figure 4 is a matrix showing which studies (in rows) reported which outcomes (in columns). Empty cells indicate that the study did not report the outcome. Cells with white markers indicate that a study reported an outcome but the outcome was not used in a meta-analysis. Cells with black markers indicate that a study reported an outcome that was used in a meta-analysis.

### Knowledge About the Condition or the Available Options

We identified 44 trials assessing the effect of decision aids on factual knowledge about the decision at hand. In total, 38 trials (corresponding to 42 compared strata and 12,484 participants) reported numerical data necessary for analysis.^b^ The analysis informs on the effects of using versus not using decision aids, and on the comparative effectiveness of decision aids with different characteristics. Because trials measured knowledge differently, we standardized the mean scores in each arm by the pooled sample standard deviation of responses in each trial, effectively calculating standardized mean differences (SMD). Almost all trials were deemed to be at a low or moderate risk of bias for this outcome.

b Results from trials not included in the analyses are not explicitly reported in this document, and are available at the SRDR site for this project (http://srdr.ahrq.gov/projects/143, last accessed October 12, 2014). Overall, data from studies that are not included in the quantitative analysis are congruent with the herein presented quantitative analysis.

Overall, using decision aids resulted in higher knowledge scores (SMD = 0.23, 95% credible interval [CrI]: 0.05, 0.35) compared with not using them. An SMD of 0.20 to 0.30 can be considered a small to moderate effect.114 The effect appeared to be more pronounced among those at high risk of cancer (0.35, 95% CrI: 0.05, 0.70) compared with people at average risk (0.22, 95% CrI: 0.04, 0.36) or patients with early cancer (0.25, 95% CrI: -0.02, 0.57). However, the differences in the effect of knowledge across population groups were not beyond what could be explained by chance.

Between-study heterogeneity was substantial. Table 3 lists the results of meta-regressions seeking to explain it. Effects on knowledge did not differ beyond chance by the examined characteristics of decision aids. However, some attributes of the decision aids explain part of the between-study variability. For example, the difference in knowledge scores between decision aids and control appears to be higher (albeit not beyond chance) for decision aids that are implemented as software or on the web, present generic probabilities of outcomes, or are used by only by patients. Although the credible intervals were wide, the effectiveness of decision aids did not appear to differ by whether the delivery of the decision aid included a human (person providing logistical help, a support group, use of a patient navigator), was tailored to a target population, used by the patient and the provider, or used by the patient only. Finally, the effectiveness of decision aids did not differ by the presence or absence of methodological quality items.

Table 3 Effects of decision aids on knowledge about the condition or the available options

Analysis (Attribute of the Decision Aid) | Effect Without Attribute | Effect With Attribute | Difference (With Vs. Without) | Between-Study SD
Overall (42 comparison strata, 12,484 participants) | 0.23 (0.09, 0.35)^*^ | | | 0.32
Decision aid format
Audiovisual material | 0.23 (0.12, 0.34)^*^ | 0.27 (0.10, 0.46)^*^ | 0.04 (-0.10, 0.21) | 0.29
Software or website | 0.17 (0.10, 0.23)^*^ | 0.45 (0.02, 0.94)^*^ | 0.28 (-0.15, 0.77) | 0.14
Printed material | 0.23 (0.12, 0.35)^*^ | 0.23 (0.13, 0.35)^*^ | 0.01 (-0.04, 0.06) | 0.30
In-person education | 0.23 (0.11, 0.33)^*^ | 0.33 (-0.84, 1.49) | 0.11 (-1.07, 1.27) | 0.27
Option grid | 0.24 (0.10, 0.38)^*^ | 0.06 (-0.75, 0.86) | -0.19 (-1.01, 0.63) | 0.35
Decision board | 0.24 (0.08, 0.37)^*^ | 0.13 (-1.36, 1.69) | -0.11 (-1.59, 1.47) | 0.34
Decision aid content
Explicit values clarification | 0.23 (0.09, 0.36)^*^ | 0.23 (0.08, 0.38)^*^ | -0.00 (-0.13, 0.15) | 0.31
Probability of outcomes (generic) | 0.10 (-0.01, 0.26) | 0.30 (0.05, 0.52)^*^ | 0.20 (-0.10, 0.43) | 0.12
Probability of outcomes (personalized) | 0.24 (0.08, 0.38)^*^ | 0.19 (-0.07, 0.41) | -0.06 (-0.29, 0.17) | 0.35
Others' opinions | 0.22 (0.08, 0.34)^*^ | 0.24 (0.10, 0.36)^*^ | 0.02 (-0.02, 0.06) | 0.31
Coaching in decision making (human mediated) | 0.23 (0.12, 0.34)^*^ | 0.22 (-0.13, 0.55) | -0.02 (-0.37, 0.33) | 0.22
Guidance in decision making (non-human-mediated) | 0.24 (0.13, 0.36)^*^ | 0.22 (0.03, 0.40)^*^ | -0.01 (-0.22, 0.15) | 0.29
Decision analytic model | 0.24 (0.12, 0.37)^*^ | 0.11 (-1.30, 1.59) | -0.13 (-1.53, 1.35) | 0.31
Other attributes of the decision aid
Developed based on theory | NE | NE | NE | NE
Needing a human to deliver | 0.20 (0.01, 0.34)^*^ | 0.23 (0.07, 0.37)^*^ | 0.02 (-0.03, 0.14) | 0.36
Tailored to target population | 0.23 (0.09, 0.36)^*^ | 0.25 (-0.16, 0.66) | 0.02 (-0.41, 0.45) | 0.33
Used by patient and provider | 0.27 (0.15, 0.39)^*^ | 0.05 (-0.29, 0.30) | -0.21 (-0.58, 0.04) | 0.30
Used by patient only | 0.08 (-0.09, 0.30) | 0.27 (0.10, 0.45)^*^ | 0.18 (-0.09, 0.42) | 0.17
Includes human for logistical support | 0.23 (0.07, 0.36)^*^ | 0.23 (0.07, 0.36)^*^ | -0.00 (-0.02, 0.02) | 0.31
Includes support group | 0.23 (0.11, 0.35)^*^ | 0.42 (-2.13, 3.00) | 0.20 (-2.37, 2.77) | 0.32
Includes patient navigator | NE | NE | NE | NE
Methodological quality items
Adequate random sequence generation | 0.21 (0.01, 0.48)^*^ | 0.24 (0.02, 0.41)^*^ | 0.02 (-0.38, 0.30) | 0.28
Allocation concealment | 0.17 (-0.05, 0.40) | 0.27 (0.01, 0.46)^*^ | 0.11 (-0.30, 0.37) | 0.33
Outcome assessor masking | 0.24 (0.06, 0.39)^*^ | 0.21 (-0.06, 0.49) | -0.03 (-0.32, 0.30) | 0.33
Attrition rate <20% | 0.23 (0.10, 0.37)^*^ | 0.26 (-0.17, 0.68) | 0.02 (-0.43, 0.46) | 0.32

* 95% credible interval does not include 0.

NE = not estimable (analysis not converged or very wide 95% credible intervals); SD = standard deviation.

We also ran analyses where in addition to the factors listed in Table 3, we adjusted for population groups (screening, high risk for cancer, early cancer), and decision aid interactions across these groups. These analyses did not provide evidence that population groups modify the interaction effects (not shown for parsimony).

In summary, use of decision aids increases knowledge moderately albeit variably; the observed efficacy did not vary across population subgroups with different characteristics or across decision aid attributes.

### Congruence Between Choices/Values and Informed Choices

Two trials (1,079 participants) compared decision aids versus a non-decision aid control with respect to congruence between actual choices and patient values for decisions related to prevention of breast cancer with hormonal therapy,41 and treatment of localized prostate cancer.33 Both were deemed to be at low risk of bias. One found that women in the decision aid arm showed alignment between values and choices significantly more often than the control arm.41 The other documented no statistical difference between actual choices and patient concerns.

Five trials (2,406 participants) compared the proportion of people making an informed choice between decision aids and a non-decision aid control among people at average64,65,87,92 and high risk41 of cancer. Informed choice was defined variably across trials to capture people who made a choice and had adequate knowledge. All trials were deemed to be at low risk of bias for this outcome. All but one65 found that the frequency of informed choices was statistically significantly higher in decision aid groups compared with control groups.

Another four trials (970 participants) reported on the proportion of patients who answered a question about whether they believed they had made an informed choice.45,46,101,102 Three trials documented statistically significantly higher frequency of perception of making an informed choice among those using versus not using decision aids, and one found no significant difference. However, these results are not easy to interpret, because of the high risk of cognitive bias115 for this outcome.

In summary, in most studies use of decision aids was statistically significantly associated with better indices of informed choice. Yet the assessment of informed choice showed great variety across studies ranging from a single unvalidated question to validated instruments.

### Accurate Perception of Mortality Risk

Nine trials (2,454 participants) evaluated the accuracy of perception of mortality risks among people at average risk of cancer,45,88,108 at high risk of cancer,27,50,61 and with early cancer.76,81,104 Determining each trial's risk of bias for this outcome is greatly hindered by the lack of details about its assessment. Thus, operationally, eight trials were deemed to be at moderate and one88 at low risk of bias. Results across all trials suggested that participants receiving decision aids more often had accurate perceptions of long-term (e.g., over 10 years) or lifetime risk of dying, or other risks (e.g., developing cancer). Such findings reached statistical significance in five trials.45,61,76,81,104 Because trials differed in the risks they examined, and how they assessed the accuracy of risk perception, it is not straightforward to characterize the importance of the observed effects of decision aids versus control, and impossible to examine the role of effect modifiers.

### Decisional Conflict

We identified 33 trials assessing the effect of decision aids on decisional conflict. In total, 28 trials (7,923 participants) reported data about mean differences in the Decisional Conflict Scale (DCS).^c^ The DCS instrument has been validated in various geographical and language settings as well as in low literacy groups.16 We translated all DCS scores into a 0-100 scale so that higher scores mean higher levels of conflict. No information was available about what difference in DCS is clinically important. However, the manual of the DCS questionnaire suggests to power studies for a clinically significant difference in the effect size^d^ of about 0.3, and we use this as a proxy for an important difference. The effect size translates to a difference of approximately 5 units in a DCS scale of 0 to 100, while the standard deviation of responses is about 15 units on a 0-100 scale.^e^ Almost all trials were deemed to be at a low or moderate risk of bias for this outcome. Overall, there were no large differences in the DCS between using and not using decisions aids, assessed shortly after the completion of the intervention. The weighted mean difference (WMD) was -5.3 (95% CrI: -8.9, -1.8), indicating slightly lower mean decisional conflict scores in decision aids compared with controls.

c Results from trials not included in the analyses are not explicitly reported in this document, and are available at the SRDR site for this project (http://srdr.ahrq.gov/projects/143, last accessed October 12, 2014). Overall, data from studies that are not included in the quantitative analysis are congruent with the herein presented quantitative analysis.

d We interpreted “effect size” as standardized effect size.

e This is (rounded) the median standard deviation for this outcome in the included studies.

The difference appeared more pronounced among those at high risk of cancer (-8.0, 95% CrI: -14.8, -1.3) compared with people at average risk (-4.2, 95% CrI: -10.2, 1.7) or patients with early cancer (-4.2, 95% CrI: -10.1, 1.9). However, differences in effect across population groups was not beyond what was expected by chance.

Between-study heterogeneity was small. Table 4 lists the results of meta-regressions seeking to explain it. The difference in the DCS scale between decision aids and control interventions, was of similar magnitude for all decision aids that have the characteristics examined in Table 4. There were no differences beyond chance when studies were stratified by the presence or absence of methodological quality items after adjusting for population group.

Table 4 Effects of decision aids on the Decisional Conflict Scale (on a 0–100 scale)

Analysis (Attribute of the Decision Aid) | Effect Without Attribute | Effect With Attribute | Difference (With Vs. Without) | Between-Study SD
Overall (28 comparison strata, 7,923 participants) | -5.3 (-8.9, -1.8)^*^ | | | 8.1
Decision aid format
Audiovisual material | -5.3 (-8.9, -1.8)^*^ | -4.2 (-13.3, 4.9) | 1.2 (-7.7, 10.0) | 8.1
Software or website | -3.8 (-5.4, -2.5)^*^ | -6.0 (-11.4, -0.7)^*^ | -2.2 (-7.7, 3.2) | 1.7
Printed material | -5.2 (-9.3, -1.3)^*^ | -5.3 (-9.1, -1.4)^*^ | -0.1 (-2.4, 3.3) | 8.2
In-person education | -5.6 (-10.0, -1.4)^*^ | -4.1 (-12.0, 3.9) | 1.5 (-7.3, 11.0) | 8.3
Option grid | -5.3 (-9.0, -1.5)^*^ | -5.0 (-19.3, 9.4) | 0.3 (-14.6, 15.2) | 8.3
Decision board | -5.3 (-9.0, -1.6)^*^ | -5.1 (-19.3, 9.6) | 0.2 (-14.5, 15.0) | 8.2
Decision aid content
Explicit values clarification | -5.8 (-11.7, -0.8)^*^ | -5.4 (-9.7, -1.1)^*^ | 0.1 (-4.3, 7.0) | 8.2
Probability of outcomes (generic) | -7.2 (-12.9, -1.6)^*^ | -4.1 (-9.0, 0.6) | 3.0 (-4.2, 10.4) | 8.0
Probability of outcomes (personalized) | -4.6 (-8.3, -1.0)^*^ | -6.1 (-12.2, -0.2)^*^ | -1.4 (-8.2, 4.6) | 6.8
Others' opinions | -5.7 (-9.8, -1.8)^*^ | -5.0 (-9.3, -0.9)^*^ | 0.5 (-2.6, 4.9) | 8.0
Coaching in decision making (human mediated) | -4.5 (-8.9, -0.3)^*^ | -6.5 (-13.4, 0.2) | -2.0 (-10.0, 5.9) | 8.1
Guidance in decision making (non-human-mediated) | -5.7 (-9.6, -1.9)^*^ | -4.5 (-9.5, 0.9) | 1.1 (-3.5, 6.7) | 8.2
Decision analytic model | -5.5 (-9.2, -1.8)^*^ | -2.1 (-17.3, 12.0) | 3.4 (-12.1, 17.8) | 8.2
Other attributes of the decision aid
Developed based on theory | NE | NE | NE | NE
Needing a human to deliver | -7.9 (-13.4, -2.8)^*^ | -5.3 (-9.0, -1.6)^*^ | 2.6 (-1.2, 7.0) | 8.2
Tailored to target population | -4.1 (-6.7, -1.8)^*^ | -9.0 (-16.9, -1.1)^*^ | -4.8 (-12.7, 3.1) | 4.3
Used by patient and provider | -5.7 (-9.9, -1.6)^*^ | -3.9 (-12.3, 4.0) | 1.8 (-7.3, 10.6) | 8.3
Used by patient only | -3.5 (-6.9, -0.4)^*^ | -5.7 (-10.0, -1.5)^*^ | -2.3 (-7.3, 3.1) | 2.3
Includes human for logistical support | -4.9 (-8.7, -1.1)^*^ | -5.3 (-8.9, -1.7)^*^ | -0.4 (-1.5, 0.9) | 8.2
Includes support group | NE | NE | NE | NE
Includes patient navigator | -5.3 (-9.0, -1.7)^*^ | -4.6 (-24.5, 15.8) | 0.7 (-19.3, 21.7) | 8.2
Methodological quality items
Adequate random sequence generation | -3.1 (-5.4, -0.8)^*^ | -6.2 (-11.0, -1.5)^*^ | -3.1 (-8.5, 2.1) | 1.9
Allocation concealment | -2.9 (-5.7, 0.2) | -8.0 (-13.9, -2.3)^*^ | -5.2 (-11.6, 1.3) | 3.7
Outcome assessor masking | -5.7 (-9.7, -1.7)^*^ | -3.5 (-12.9, 6.3) | 2.2 (-7.9, 12.7) | 8.3
Attrition rate <20% | -5.5 (-9.6, -1.5)^*^ | -4.5 (-12.8, 3.4) | 1.0 (-8.1, 9.6) | 8.3

* 95% credible interval does not include 0.

NE = not estimable (analysis not converged or very wide 95% credible intervals); SD = standard deviation.

In summary, use of decision aids seems to lower decisional conflict, although the effect is not large. The observed efficacy was not mediated by characteristics of the decision aid or the methodological quality of the assessed studies.

### Patient-Provider Communication

A single trial in 256 men with early prostate cancer70 compared two decision aid-based intervention arms (booklet, DVD, phone call by a nurse; same plus calls to a designated primary support person) and a control arm with respect to the Patient-Provider Communication Scale. Operationally, its risk of bias for the outcome was deemed moderate, because of incomplete reporting of study procedures. People in intervention arms had higher scores than those in the control arm at 1 month but the difference dissipated at 3 months of followup.

### Patient Participation in Decision Making

Patient participation in decision making was reported in four trials totaling 1,549 people facing prostate cancer screening decisions,72,85,98,106 one trial of 88 women with BRCA1/2 mutations,93 and three trials in 536 patients requiring treatment for prostate cancer36,37 or breast cancer.95 Six of the eight trials compared decision aids versus control (e.g., usual care, video for irrelevant topic), and the other two compared decision aids between them (entertainment-based vs. non-entertainment-based decision aid,98 individualized decision support vs. informational video37). Patient participation in decision making was self-reported in seven trials and by a third party in one.72

Overall, there were no strong indications for important effects of decision aids on this outcome. Six trials found no significant differences between decision aids and non-decision aid controls, or between different decision aids. Two trials found significant differences indicating higher patient participation in decision making in the decision aid versus control.37,72 Evaluating trials' risk of bias with respect to this outcome category is hindered by the lack of detail about its quantification; operationally, no trial was deemed to be at a high risk of bias.

### Proportion Undecided

Two trials (1,046 people) of decision aids about mammography screening,64,65 one (1,197 people) on hormonal treatment for breast cancer prevention,41 and one (240 patients) on treatments of prostate cancer94 reported differences in the proportion of undecided people between decision aids and non-decision aid controls. Results across all trials suggested that participants receiving decision aids were statistically significantly less likely to be undecided compared with those in the control group. With respect to this outcome, one trial41 was deemed to be at high risk of bias because of large non-response rates, and the other three were deemed to be at low risk of bias. Because the trials are about different decisions, it is not straightforward to characterize the importance of the observed effects. It was not possible to examine the role of effect modifiers.

### Patient Satisfaction With Decision-Making Process

Patient satisfaction with the decision-making process^f^ was reported in one trial in 665 persons making decisions about colorectal screening,82 and three trials in 466 women facing decisions about breast cancer treatment.57,95,105 The trial about screening decisions82 had three arms (interactive computerized decision aid vs. the same plus an online risk calculator vs. a Web site with generic discussion of lifestyle changes), while the other three trials compared decision aids versus non–decision-aid controls. In all, for comparisons of decision aids versus control, two of four trials found statistically significantly higher satisfaction with decision aids, and two found no statistically significant differences. In the three-arm trial there was no significant difference between the two decision aid-based arms. Self-rated patient satisfaction scores may favor the decision aid for reasons such as low initial expectations and no experience with a meaningful shared decision-making process, or reluctance to second guess a previous decision.116 Therefore, the importance of differences in the satisfaction scores is not straightforward to assess, and the risk of bias of all studies for this outcome was operationally deemed to be unclear. It was not possible to examine the role of effect modifiers.

f Measured with the Satisfaction with Decisionmaking Process Scale,108 with a subscale of the Decisional Conflict Scale,11 or with a custom question.

### Actual or Intended Choices

Overall, 49 trials examined the effectiveness of decision aids with respect to actual or intended choices for the decisional problems at hand. The trial reports were published between 1997 and 2014 and almost two-thirds of the studies were conducted in the USA (n=29), with Australia being the second most common country (n=12). Seven trials were cluster-randomized trials and 12 trials included multiple centers. Eighteen and fourteen trials were conducted in a primary care and specialized care setting, respectively. The majority (n=30 trials) were about screening-related decisions, 7 assessed decisions pertaining to high genetic risk of cancer, and 12 assessed cancer-treatment decisions.

The 49 trials mostly compared one or more decision aids with a non-decision aid control (e.g., usual care/no intervention, generic information pamphlet), however seven trials compared between decision-aid based interventions without including a control. Most trials (n=20) examined actual choices^g^ only, 16 examined only intended choices,^h^ and 13 both intended and actual choices. Actual or intended choice was the primary outcome in 20 studies.

g Defined as ordering or completing a screening test or completing a treatment, and assessed through self-reporting or by cross-checking health records.

h Self-reported response to a single question assessed at the end of the intervention or at a short followup time point.

Most studies were deemed to be at a low or moderate risk of bias for this outcome. Random sequence generation was clearly reported in two-thirds of the studies (n=31) with unclear reporting in the remaining one-third. Allocation concealment was achieved in half of the studies, through central randomization. Masking to group assignment was generally difficult to achieve, but it is not clear how this would bias assessments. Small attrition rates (below 20%) were reported in five out of 49 trials.

There was considerable diversity in the number and nature of choices across trials, and a quantitative synthesis was not done. However, one can obtain indications about the impact of decision aids on choices, by comparing the distributions of proportions between arms in each trial. Significant differences, irrespective of direction, imply an effect for decision aids. Seventy eight such comparisons were done in the 49 trials, and 19 were statistically significant. However, there was no association between a significant association and year of publication, sample size, type of choice (screening or treatment), or methodological items (random sequence generation, allocation concealment, assessor masking, attrition rate less than 20%).

The two largest studies evaluating choices pertained to breast64 and prostate screening.90 The breast screening trial compared a decision aid providing balanced information with usual care in 734 women in Australia, and found no difference in screening rates at one month. The prostate screening trial compared a print-based decision aid, a web-based interactive decision aid, or usual care in 1,879 participants in the US, and also found no significant difference at 13 months. The largest study with statistically significant results for actual choice87 was done in 572 people in Australia for decisions related to colon cancer screening, and found both increased knowledge and lower rates of screening participation in the decision aid group compared with usual care. The authors attribute this to increased “knowledge about the low personal benefit of screening.”87 The remaining studies with a statistically significant result for actual choice were of a smaller sample size (<100 participants per arm) or showed the statistically significant result in a subgroup analysis.

### Anxiety

We identified 24 trials that assessed anxiety using various instruments. The majority used the State-Trait Anxiety Inventory (n=14), eight used the Hospital Anxiety and Depression Score (HADS) and two used other instruments. In total, 12 trials (16 comparison strata with 2,958 participants) reported mean differences in the state or total score of the State-Trait Anxiety Inventory (STAI), which is a self-reported psychological inventory that has been validated in numerous settings.^i^ Almost all trials were deemed to be at a low or moderate risk of bias for this outcome.

i STAI differences are reported in a 20-80 scale (20 lowest, 80 highest anxiety). Results from trials using other instruments were included in a sensitivity analysis using SMDs. The results of the sensitivity analysis were qualitatively similar to the results reported for STAI.

No information was available about what difference in STAI is clinically important. However, the differences observed in Table 5 are very small with respect to the range of the scale, which is from 20 to 80 points. The weighted mean difference (WMD) was 0.1 (95% CrI: -1.0, 0.7). Mean anxiety did not differ beyond chance between those at average risk of cancer (0.1, 95%CrI: -1.3, 1.1), high risk of cancer (-0.8, 95% CrI: -2.9, 1.3) and early cancer (0.02, 95% CrI -2.9, 3.4).

Table 5 Effects of decision aids on the state or total score with the State-Trait Anxiety Inventory (on a 20-80 scale)

Analysis Attribute of the Decision Aid) | Effect Without Attribute | Effect With Attribute | Difference (With vs. Without) | Between-Study SD
Overall (16 comparison strata with 2958 participants) | 0.1 (-1.0, 0.7) | | | 0.5
Decision aid format
Audiovisual material | 0.1 (-1.2, 0.8) | 0.4 (-7.2, 8.0) | 0.4 (-7.1, 8.0) | 0.5
Software or website | 0.1 (-1.2, 1.3) | -0.6 (-2.6, 0.9) | -0.8 (-2.4, 0.9) | 0.6
Printed material | -0.4 (-2.4, 1.7) | -0.1 (-1.6, 1.1) | 0.3 (-2.0, 2.4) | 0.5
In-person education | 0.2 (-1.0, 1.0) | -0.8 (-4.3, 2.8) | -0.9 (-4.5, 2.8) | 0.5
Option grid | 0.1 (-1.1, 0.9) | -0.9 (-6.9, 4.8) | -1.0 (-6.9, 4.9) | 0.5
Decision board | 0.1 (-1.1, 0.9) | -0.8 (-6.7, 4.8) | -0.9 (-6.8, 4.8) | 0.5
Decision aid content
Explicit values clarification | -0.3 (-1.8, 1.2) | -0.1 (-3.1, 2.5) | 0.2 (-3.1, 3.2) | 0.5
Probability of outcomes (generic) | -0.4 (-2.4, 1.6) | -0.0 (-1.7, 1.2) | 0.3 (-2.3, 2.5) | 0.6
Probability of outcomes (personalized) | 0.1 (-1.1, 1.0) | -0.7 (-7.8, 6.0) | -0.7 (-7.8, 6.0) | 0.5
Others' opinions | -0.2 (-1.5, 1.0) | -1.0 (-6.1, 3.4) | -0.9 (-5.7, 3.7) | 0.6
Coaching in decision making (human mediated) | 0.2 (-1.1, 1.1) | -0.8 (-3.8, 2.3) | -0.9 (-4.1, 2.3) | 0.5
Guidance in decision making (non-human-mediated) | 0.1 (-1.1, 0.8) | 0.1 (-13.0, 13.4) | 0.1 (-13.0, 13.5) | 0.5
Decision analytic model | 0.1 (-1.0, 0.8) | -2.1 (-15.3, 11.3) | -2.2 (-15.3, 11.3) | 0.4
Other attributes of the decision aid
Developed based on theory | NE | NE | NE | NE
Needing a human to deliver | 0.3 (-0.7, 1.3) | -0.6 (-1.7, 0.6) | -0.8 (-1.9, 0.2) | 0.5
Tailored to target population | 0.1 (-1.2, 0.9) | -0.1 (-12.9, 12.5) | -0.2 (-12.9, 12.5) | 0.5
Used by patient and provider | 0.1 (-1.2, 0.8) | -0.4 (-10.4, 7.5) | -0.4 (-10.4, 7.6) | 0.5
Used by patient only | 0.3 (-3.5, 4.1) | -0.1 (-1.6, 1.0) | -0.5 (-4.6, 3.6) | 0.5
Includes human for logistical support | -0.7 (-2.1, 0.5) | 0.1 (-1.1, 1.2) | 0.8 (-0.3, 1.8) | 0.5
Includes support group | NE | NE | NE | NE
Includes patient navigator | NE | NE | NE | NE
Methodological quality items
Adequate random sequence generation | -0.0 (-2.7, 2.5) | -0.1 (-1.7, 1.1) | -0.1 (-3.0, 2.8) | 0.5
Allocation concealment | -0.4 (-2.7, 1.9) | -0.0 (-1.6, 1.3) | 0.3 (-2.4, 2.9) | 0.6
Outcome assessor masking | 0.1 (-1.1, 1.0) | -0.4 (-3.3, 2.4) | -0.5 (-3.6, 2.5) | 0.5
Attrition rate <20% | 0.1 (-1.2, 0.9) | -0.5 (-9.0, 7.2) | -0.5 (-9.0, 7.2) | 0.5

Notes: NE = not estimable (nonconvergence or very wide 95% credible intervals); SD = standard deviation.

Between-study heterogeneity was small. Table 5 lists the results of meta-regressions seeking to explain it. Analyses suggest that effects on STAI did not differ substantially by any of the examined characteristics of decision aids, the studies, or their methodological items (Table 5). Sensitivity analyses adjusting the factors in Table 5 for population groups did not provide additional information (not shown).

### Depression and Emotional Distress

For depression and emotional distress (worry or presence of intrusive thoughts) we did not have enough trials to perform quantitative analyses. Nine trials (four in people at high risk of cancer, and five in people with early cancer) reported assessing depression outcomes using the Hospital Anxiety and Depression Scale or the Center for Epidemiologic Studies Depression Scale,36,59,63,91,93,96,101,102,105 but only four59,91,93,105 provided analyzable information. Both for comparisons of using versus not using decision aids and for comparisons between decision aids the magnitudes of reported effects were small, and statistically nonsignificant. It was not possible to examine the role of effect modifiers.

Finally, eight trials reported results with respect to emotional distress or worry (three in people at average risk and four in people at high risk of cancer, and one early cancer).45,46,62,64,66,84,91,93 In all, no large differences were found in any study, both for comparisons of using versus not using decision aids,46,62,64,66,84,91,93 and for comparisons between decision aids.45,46 It was not possible to examine the role of effect modifiers.

### Decision Regret

Eight trials (1075 participants) reported results for decision regret from another instrument between 1 month and 1 year of followup.42,47,52,59,70,101,102,108 Most studies used the Decision Regret Scale,22 and one used the decision regret subscale of a quality of life scale.117 All compared decision aids versus no decision aids, and one70 also compared between two decision aids. Overall, use of decision aids was not consistently associated with higher or lower decision regret (lower in four trials, higher in three) compared with not using decision aids. No important differences were found in any study, both for comparisons of using versus not using decision aids, and for comparisons between decision aids. It was not possible to examine the role of effect modifiers.

### Quality of Life

Four trials comparing decision aids versus control reported data on quality of life for a total of 777 patients, using a variety of scales (e.g., generic questions, SF-36); one on decisions about cervical cancer screening,66 one about preventive treatments in women at high genetic risk for breast and ovarian cancer,93 and two about treatment of early breast cancer63 or prostate cancer.70 In all, differences in quality of life favored decision aids versus control interventions; the difference was statistically significant in one trial,63 and only for long-term followup in another.93 The magnitude of the differences was small, and thus of unclear clinical importance. Assessment of the risk of bias for this outcome was not straightforward, because of unclear reporting of trial design, trial procedures or of details in outcome assessment. Operationally, the four trials were deemed at moderate risk of bias for this outcome. It was not possible to examine the role of effect modifiers.

### Resource Use

One Australian trial of 314 women with borderline results in cervical cancer screening compared the number of calls to the provider clinic and visits to the practitioner in three arms: a decision aid about further work-up options versus usual care (Pap smear after 6 months) versus molecular human papillomavirus screening.66 The trial found no statistically significant difference between the three arms, overall, or across any two. (The median number of follow-up calls and of visits was 0 in all arms) The risk of bias for this outcome was deemed to be low.

### Length of Consultation

Three trials (417 participants) compared decision aids versus control with respect to length of consultation in women at high risk of breast cancer facing further diagnostic or preventive treatment decisions50,73 and in women with early breast cancer facing treatment decisions.105 In a trial of women at risk to be BRCA mutation carriers the length of consultation was shorter in the decision aid arm, but this result was driven by the subgroups who were at low risk. No clinically or statistically significant difference was reported in the two other trials. Because of unclear reporting of trial design, trial procedures or details in outcome assessment, assessment of the risk of bias for this outcome was not straightforward. Operationally, the trials were deemed at moderate risk of bias for this outcome. It was not possible to examine the role of effect modifiers.

### Other Outcomes

None of the included trials reported data on the prespecified outcomes of costs or litigation rates.

### Sensitivity Analyses

Results of sensitivity analyses were qualitatively similar with the results described above. Limiting quantitative synthesis to the studies included in the recent update of the Cochrane review did not result in appreciable differences for the main effects of decision aids versus control, or for the modification of effects by population risk of cancer or presence of cancer, characteristics of the decision aid (format, content, need for delivery by a human, or other attributes, as listed in Tables 3, 4 and 5). Use of more uncertain priors for the modeling resulted in somewhat broader confidence intervals; the greatest sensitivity was observed to priors on parameters related to between-study heterogeneity for main or interaction effects. Results were similar when we used alternative imputations for missing standard deviations (1.2 or 0.8 times the median in the observed studies), and when we also included data extracted based on tenuous assumptions.

## Results for Key Question 2

Promotion of shared decision making on the part of health care providers in cancer screening or early cancer treatment was examined in only five studies:109-113 two studies on screening for prostate cancer and one study on screening for colorectal cancer.

One study cluster randomized 227 Australian general practitioners in 220 practices to a combination of informational packages and three motivational peer-coaching sessions over three months, or to mailed summaries of PSA screening guidelines (control).109 At the end of the three months, practitioners in the active intervention group were more likely to report that they always engaged in several behaviors facilitating informed decision making (e.g., questioned men about whether they understood the pros and cons of PSA testing), and were less likely to agree that patients should remain passive when making decisions about PSA screening.

The second study randomized 120 California primary care physicians in five clinics to brief Web-based interactive physician education on prostate cancer screening or to a standard Centers for Disease Control and Prevention brochure (control).111 Standardized patients visited the physicians approximately three months after enrollment in the study, and recorded the encounters. Transcription and coding of the encounters revealed that intervention physicians engaged in a mean of 14 shared decision-making behaviors compared with a mean of 11 behaviors in control physicians. However behaviors related to elicitation of patient perspectives were infrequent and did not differ between intervention groups.

The third study examined an intervention to increase the distribution of decision aids at five California primary care clinics.110 The study team used several strategies over 30 months to promote the distribution of decision aids, including academic detailing and training sessions for providers and staff. Increases in distribution rates in response to promotional activities were brief, and only 9.3 percent of patients eligible for colorectal cancer screening received a decision aid. The authors suggested several changes in health care practice and policy are necessary for shared decision making to become a part of routine clinical practice, including a supportive team-based clinic culture, ongoing provider training in communication and shared decision-making skills, and implementation of incentives for patient engagement.

The study by Uy113 explored the impact of a financial incentive on prescribing of decision support interventions across a variety of medical decisions (including a number related to cancer) in 4 practices. The physician or the clinical staff would receive a $15 incentive per prescription. Overall, the financial incentive increased prescribing by 71 percent although the results of the study were mixed. There were physician views that the financial incentive had no effect on the prescribing pattern, while there were also cases where, once no further incentives were available, prescribing ceased altogether.

Finally, an abstract112 published in 2014 assessed the impact of an academic detailing intervention consisting of a single interactive case-based discussion. The discussion included 30 minutes of risk/benefits, individual risk assessment, and counseling methods and participants were providers and nursing staff in 13 outpatient Veterans Affairs clinics. The investigators explored the impact of the intervention on knowledge and attitudes of providers regarding breast cancer screening recommendations for women ages 40-50. After the intervention, breast cancer screening recommendations were different, attitudes favoring discussion of benefits increased from 94 percent to 99 percent with no statistically significant difference, and attitudes favoring discussion of risks increased statistically significantly from 34 percent to 90 percent. Moreover, the comfort level of discussing benefits, risks and preferences also increased.

The five studies were deemed to be at low to moderate risk of bias for the range of outcomes they described. It was not possible to examine the role of effect modifiers because data were not available.