# References

1 Keeney RL, Raiffa H. Decisions with multiple objectives: preferences and value trade-offs. Cambridge, UK. Cambridge University Press. 1993.
2 Pratt JW, Raiffa H, Schaifer R. Introduction to statistical decision theory. Cambridge, MA. MIT Press. 1995.
3 IPDAS. International Patient Decision Aid Standards Collaboration - methodology document. 2012. http://ipdas.ohri.ca. July 22 2013.
4 Stacey D, Legare F, Col NF, et al. Decision aids for people facing health treatment or screening decisions. The Cochrane database of systematic reviews. 2014;1. CD001431.
5 Sajid S, Kotwal AA, Dale W. Interventions to improve decision making and reduce racial and ethnic disparities in the management of prostate cancer: a systematic review. Journal of general internal medicine. Aug. 2012;27(8):1068-1078. [pmid: 22798216].
6 Spiegle G, Al-Sukhni E, Schmocker S, et al. Patient decision aids for cancer treatment: Are there any alternatives?. Cancer. Jul. 18. 2013;119(1):189-200. [pmid: 22811383].
7 O'Brien MA, Whelan TJ, Villasis-Keever M, et al. Are cancer-related decision aids effective? A systematic review and meta-analysis. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Feb. 20. 2009;27(6):974-985. [pmid: 19124808].
8 Whelan T, O'Brien MA, Villasis-Keever M, et al. Impact of cancer-related decision aids. Evid Rep Technol Assess (Summ). Jul. 2002;(46):1-4. [pmid: 12387097].
9 Smith SK, Kearney P, Trevena L, Barratt A, Nutbeam D, McCaffery KJ. Informed choice in bowel cancer screening: a qualitative study to explore how adults with lower education use decision aids. Health expectations: an international journal of public participation in health care and health policy. Aug. 2014;17(4):511-522. [pmid: 22512746].
10 Smith SK, Simpson JM, Trevena LJ, McCaffery KJ. Factors Associated with Informed Decisions and Participation in Bowel Cancer Screening among Adults with Lower Education and Literacy. Medical decision making: an international journal of the Society for Medical Decision Making. Jan. 13. 2014;34(6):756-772. [pmid: 24421292].
11 Mack LA, Cook LS, Temple WJ, Carlson LE, Hilsden RJ, Paolucci EO. Colorectal cancer screening among first-degree relatives of colorectal cancer patients: benefits and barriers. Annals of surgical oncology. Aug. 2009;16(8):2092-2100. [pmid: 19479307].
12 Trikalinos TA, Shields R, Zgodic A, Wieland LS. Decision support tools for early cancer: Topic refinement. 2013.
13 Legare F, Ratte S, Stacey D, et al. Interventions for improving the adoption of shared decision making by healthcare professionals. The Cochrane database of systematic reviews. 2010;(5). CD006732.
14 REDACTED. Blue Cross Blue Shield Association Technology Evaluation Center Evidence-based Practice Center. Decision support tools for cancer decisions: Topic Development. 2012.
15 Moher D, Liberati A, Tetzlaff J, Altman DG, Group P. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. Annals of internal medicine. Aug. 18. 2009;151(4):264-269. W264. [pmid: 19622511].
16 O'Connor AM. Validation of a decisional conflict scale. Medical decision making: an international journal of the Society for Medical Decision Making. Jan-Mar. 1995;15(1):25-30. [pmid: 7898294].
17 Spielberger CD, Gorsuch LR, Lushene R, Vagg PR, Jacobs GA. Manual for the State-Trait Anxiety Inventory. Palo Alto, CA. Consulting Psychologists Press. 1983.
18 Marteau TM, Bekker H. The development of a six-item short-form of the state scale of the Spielberger State-Trait Anxiety Inventory (STAI). The British journal of clinical psychology/the British Psychological Society. Sep. 1992;31(Pt 3):301-306. [pmid: 1393159].
19 Zigmond AS, Snaith RP. The hospital anxiety and depression scale. Acta psychiatrica Scandinavica. Jun. 1983;67(6):361-370. [pmid: 6880820].
20 SF-36.org. A community for measuring health outcomes using Short Form tools. 2014. www.sf-36.org. 01/5/2014. 2014.
21 Horowitz M, Wilner N, Alvarez W. Impact of Event Scale: a measure of subjective stress. Psychosomatic medicine. May. 1979;41(3):209-218. [pmid: 472086].
22 Brehaut JC, O'Connor AM, Wood TJ, et al. Validation of a decision regret scale. Medical decision making: an international journal of the Society for Medical Decision Making. Jul-Aug. 2003;23(4):281-292. [pmid: 12926578].
23 Wallace BC, Small KM, Brodley CE, Lau J, Trikalinos TA. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the ACM International Health Informatics Symposium (IHI). 2012.
24 Lau J, Hadar N, Iovin R, Ip S, Balk EM. Proposed Governance and Data Management Policy for the Systematic Review Data Repository. Rockville (MD). 2012. www.ncbi.nlm.nih.gov/pubmed/23101051.
25 Ip S, Hadar N, Keefe S, et al. A Web-based archive of systematic review data. Systematic reviews. 2012;1:15. [pmid: 22588052].
26 AHRQ. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. 2012. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318.
27 Albada A, van Dulmen S, Bensing JM, Ausems MG. Effects of a pre-visit educational website on information recall and needs fulfilment in breast cancer genetic counselling, a randomized controlled trial. Breast cancer research: BCR. 2012;14(2):R37. [pmid: 22394647].
28 Allen JD, Othus MK, Hart A Jr., et al. A randomized trial of a computer-tailored decision aid to improve prostate cancer screening decisions: results from the Take the Wheel trial. Cancer epidemiology, biomarkers & prevention: a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. Sep. 2010;19(9):2172-2186.
29 Auvinen A, Hakama M, Ala-Opas M, et al. A randomized trial of choice of treatment in prostate cancer: the effect of intervention on the treatment chosen. BJU international. Jan. 2004;93(1):52-56. discussion 56. [pmid: 14678367].
30 Banegas MP, McClure JB, Barlow WE, et al. Results from a randomized trial of a web-based, tailored decision aid for women at high risk for breast cancer. Patient education and counseling. Jun. 2013;91(3):364-371. [pmid: 23395006].
31 Belkora JK, Hutton DW, Moore DH, Siminoff LA. Does use of the adjuvant! model influence use of adjuvant therapy through better risk communication?. Journal of the National Comprehensive Cancer Network: JNCCN. Jul. 1. 2011;9(7):707-712. [pmid: 21715722].
32 Berry DL, Halpenny B, Hong F, et al. The Personal Patient Profile-Prostate decision support for men with localized prostate cancer: a multi-center randomized trial. Urologic oncology. Oct. 2013;31(7):1012-1021. [pmid: 22153756].
33 Berry DL, Wang Q, Halpenny B, Hong F. Decision preparation, satisfaction and regret in a multi-center sample of men with newly diagnosed localized prostate cancer. Patient education and counseling. Aug. 2012;88(2):262-267. [pmid: 22608696].
34 Bosco JL, Halpenny B, Berry DL. Personal preferences and discordant prostate cancer treatment choice in an intervention trial of men newly diagnosed with localized prostate cancer. Health and quality of life outcomes. 2012;10:123. [pmid: 23021156].
35 Chan EC, McFall SL, Byrd TL, et al. A community-based intervention to promote informed decision making for prostate cancer screening among Hispanic American men changed knowledge and role preferences: a cluster RCT. Patient education and counseling. Aug. 2011;84(2):e44-51. [pmid: 21237611].
36 Davison BJ, Degner LF. Empowerment of men newly diagnosed with prostate cancer. Cancer nursing. Jun. 1997;20(3):187-196. [pmid: 9190093].
37 Davison BJ, Goldenberg SL, Wiens KP, Gleave ME. Comparing a generic and individualized information decision support intervention for men newly diagnosed with localized prostate cancer. Cancer nursing. Sep-Oct. 2007;30(5):E7-15. [pmid: 17876177].
38 Diefenbach MA, Mohamed NE, Butz BP, et al. Acceptability and preliminary feasibility of an internet/CD-ROM-based education and decision program for early-stage prostate cancer patients: randomized pilot study. Journal of medical Internet research. 2012;14(1):e6. [pmid: 22246148].
39 Dolan JG, Frisina S. Randomized controlled trial of a patient decision aid for colorectal cancer screening. Medical decision making: an international journal of the Society for Medical Decision Making. Mar-Apr. 2002;22(2):125-139. [pmid: 11958495].
40 Evans R, Joseph-Williams N, Edwards A, et al. Supporting informed decision making for prostate specific antigen (PSA) testing on the web: an online randomized controlled trial. Journal of medical Internet research. 2010;12(3):e27. [pmid: 20693148].
41 Fagerlin A, Dillard AJ, Smith DM, et al. Women's interest in taking tamoxifen and raloxifene for breast cancer prevention: response to a tailored decision aid. Breast cancer research and treatment. Jun. 2011;127(3):681-688. [pmid: 21442198].
42 Feldman-Stewart D, Tong C, Siemens R, et al. The impact of explicit values clarification exercises in a patient decision aid emerges after the decision is actually made: evidence from a randomized controlled trial. Medical decision making: an international journal of the Society for Medical Decision Making. Jul-Aug. 2012;32(4):616-626. [pmid: 22287534].
43 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Archives of internal medicine. Feb. 25. 2008;168(4):363-369. [pmid: 18299490].
44 Frosch DL, Kaplan RM, Felitti VJ. A randomized controlled trial comparing internet and video to facilitate patient education for men considering the prostate specific antigen test. Journal of general internal medicine. Oct. 2003;18(10):781-787. [pmid: 14521639].
45 Gattellari M, Ward JE. Does evidence-based information about screening for prostate cancer enhance consumer decision-making?. A randomised controlled trial. Journal of medical screening. 2003;10(1):27-39.
46 Gattellari M, Ward JE. A community-based randomised controlled trial of three different educational resources for men about prostate cancer screening. Patient education and counseling. May. 2005;57(2):168-182. [pmid: 15911190].
47 Goel V, Sawka CA, Thiel EC, Gort EH, O'Connor AM. Randomized trial of a patient decision aid for choice of surgical treatment for breast cancer. Medical decision making: an international journal of the Society for Medical Decision Making. Jan-Feb. 2001;21(1):1-6. [pmid: 11206942].
48 Green MJ, Biesecker BB, McInerney AM, Mauger D, Fost N. An interactive computer program can effectively educate patients about genetic testing for breast cancer susceptibility. American journal of medical genetics. Sep. 15. 2001;103(1):16-23. [pmid: 11562929].
49 Green MJ, Peterson SK, Baker MW, et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genetics in medicine: official journal of the American College of Medical Genetics. Apr. 2005;7(4):221-229. [pmid: 15834239].
50 Green MJ, Peterson SK, Baker MW, et al. Effect of a computer-based decision aid on knowledge, perceptions, and intentions about genetic testing for breast cancer susceptibility: a randomized controlled trial. JAMA: the journal of the American Medical Association. Jul. 28. 2004;292(4):442-452.
51 Griffith JM, Lewis CL, Brenner AR, Pignone MP. The effect of offering different numbers of colorectal cancer screening test options in a decision aid: a pilot randomized trial. BMC medical informatics and decision making. 2008;8:4. [pmid: 18218084].
52 Hacking B, Wallace L, Scott S, Kosmala-Anderson J, Belkora J, McNeill A. Testing the feasibility, acceptability and effectiveness of a ‘decision navigation’ intervention for early stage prostate cancer patients in Scotland--a randomised controlled trial. Psycho-oncology. May. 2013;22(5):1017-1024. [pmid: 22570252].
53 Hall MJ, Manne SL, Winkel G, Chung DS, Weinberg DS, Meropol NJ. Effects of a decision support intervention on decisional conflict associated with microsatellite instability testing. Cancer epidemiology, biomarkers & prevention: a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. Feb. 2011;20(2):249-254.
54 Holt CL, Wynn TA, Litaker MS, Southward P, Jeames S, Schulz E. A comparison of a spiritually based and non-spiritually based educational intervention for informed decision making for prostate cancer screening among church-attending African-American men. Urologic nursing. Jul-Aug. 2009;29(4):249-258. [pmid: 19718941].
55 Hooker GW, Leventhal KG, DeMarco T, et al. Longitudinal changes in patient distress following interactive decision aid use among BRCA1/2 carriers: a randomized trial. Medical decision making: an international journal of the Society for Medical Decision Making. May-Jun. 2011;31(3):412-421. [pmid: 20876346].
56 Ilic D, Egberts K, McKenzie JE, Risbridger G, Green S. Informing men about prostate cancer screening: a randomized controlled trial of patient education materials. Journal of general internal medicine. Apr. 2008;23(4):466-471. [pmid: 18373146].
57 Jibaja-Weiss ML, Volk RJ, Granchi TS, et al. Entertainment education for breast cancer surgery decisions: a randomized trial among patients with low health literacy. Patient education and counseling. Jul. 2011;84(1):41-48. [pmid: 20609546].
58 Korfage IJ, Fuhrel-Forbis A, Ubel PA, et al. Informed choice about breast cancer prevention: randomized controlled trial of an online decision aid intervention. Breast cancer research: BCR. Sep. 3. 2013;15(5):R74. [pmid: 24004815].
59 Lam WW, Chan M, Or A, Kwong A, Suen D, Fielding R. Reducing treatment decision conflict difficulties in breast cancer surgery: a randomized controlled trial. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Aug. 10. 2013;31(23):2879-2885. [pmid: 23835709].
60 Lepore SJ, Wolf RL, Basch CE, et al. Informed decision making about prostate cancer testing in predominantly immigrant black men: a randomized controlled trial. Annals of behavioral medicine: a publication of the Society of Behavioral Medicine. Dec. 2012;44(3):320-330. [pmid: 22825933].
61 Lerman C, Biesecker B, Benkendorf JL, et al. Controlled trial of pretest education approaches to enhance informed decision-making for BRCA1 gene testing. Journal of the National Cancer Institute. Jan. 15. 1997;89(2):148-157. [pmid: 8998184].
62 Manne SL, Meropol NJ, Weinberg DS, et al. Facilitating informed decisions regarding microsatellite instability testing among high-risk individuals diagnosed with colorectal cancer. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Mar. 10. 2010;28(8):1366-1372. [pmid: 20142594].
63 Maslin AM, Baum M, Secker WJ, Prouse A. Shared decision-making using an interactive video disk system for women with early breast cancer. Nursing Times Research. 1998;3(6):444-454.
64 Mathieu E, Barratt A, Davey HM, McGeechan K, Howard K, Houssami N. Informed choice in mammography screening: a randomized trial of a decision aid for 70-year-old women. Archives of internal medicine. Oct. 22. 2007;167(19):2039-2046. [pmid: 17954796].
65 Mathieu E, Barratt AL, McGeechan K, Davey HM, Howard K, Houssami N. Helping women make choices about mammography screening: an online randomized trial of a decision aid for 40-year-old women. Patient education and counseling. Oct. 2010;81(1):63-72. [pmid: 20149953].
66 McCaffery KJ, Irwig L, Turner R, et al. Psychosocial outcomes of three triage methods for the management of borderline abnormal cervical smears: an open randomised trial. BMJ. 2010;340:b4491. [pmid: 20179125].
67 McCaffery KJ, Turner R, Macaskill P, Walter SD, Chan SF, Irwig L. Determining the impact of informed choice: separating treatment effects from the effects of choice and selection in randomized trials. Medical decision making: an international journal of the Society for Medical Decision Making. Mar-Apr. 2011;31(2):229-236. [pmid: 21041538].
68 Miller DP Jr., Spangler JG, Case LD, Goff DC Jr., Singh S, Pignone MP. Effectiveness of a web-based colorectal cancer screening patient decision aid: a randomized controlled trial in a mixed-literacy population. American journal of preventive medicine. Jun. 2011;40(6):608-615. [pmid: 21565651].
69 Miller SM, Fleisher L, Roussi P, et al. Facilitating informed decision making about breast cancer risk and genetic counseling among women calling the NCI's Cancer Information Service. Journal of health communication. Suppl 1. 2005;10:119-136. [pmid: 16377604].
70 Mishel MH, Germino BB, Lin L, et al. Managing uncertainty about treatment decision making in early stage prostate cancer: a randomized clinical trial. Patient education and counseling. Dec. 2009;77(3):349-359. [pmid: 19819096].
71 Myers RE, Daskalakis C, Cocroft J, et al. Preparing African-American men in community primary care practices to decide whether or not to have prostate cancer screening. Journal of the National Medical Association. Aug. 2005;97(8):1143-1154. [pmid: 16173330].
72 Myers RE, Daskalakis C, Kunkel EJ, et al. Mediated decision support in prostate cancer screening: a randomized controlled trial of decision counseling. Patient education and counseling. May. 2011;83(2):240-246. [pmid: 20619576].
73 Ozanne EM, Annis C, Adduci K, Showstack J, Esserman L. Pilot trial of a computerized decision aid for breast cancer prevention. The breast journal. Mar-Apr. 2007;13(2):147-154. [pmid: 17319855].
74 Partin MR, Nelson D, Flood AB, Friedemann-Sanchez G, Wilt TJ. Who uses decision aids? Subgroup analyses from a randomized controlled effectiveness trial of two prostate cancer screening decision support interventions. Health expectations: an international journal of public participation in health care and health policy. Sep. 2006;9(3):285-295. [pmid: 16911143].
75 Partin MR, Nelson D, Radosevich D, et al. Randomized trial examining the effect of two prostate cancer screening educational interventions on patient knowledge, preferences, and behaviors. Journal of general internal medicine. Aug. 2004;19(8):835-842. [pmid: 15242468].
76 Peele PB, Siminoff LA, Xu Y, Ravdin PM. Decreased use of adjuvant breast cancer therapy in a randomized controlled trial of a decision aid with individualized risk information. Medical decision making: an international journal of the Society for Medical Decision Making. May-Jun. 2005;25(3):301-307. [pmid: 15951457].
77 Pignone M, Harris R, Kinsinger L. Videotape-based decision aid for colon cancer screening. A randomized, controlled trial. Annals of internal medicine. Nov. 21. 2000;133(10):761-769. [pmid: 11085838].
78 Rubel SK, Miller JW, Stephens RL, et al. Testing the effects of a decision aid for prostate cancer screening. Journal of health communication. Apr. 2010;15(3):307-321. [pmid: 20432110].
79 Ruffin MTt, Fetters MD, Jimbo M. Preference-based electronic decision aid to promote colorectal cancer screening: results of a randomized controlled trial. Preventive medicine. Oct. 2007;45(4):267-273. [pmid: 17689600].
80 Salkeld G, Cunich M, Dowie J, Howard K, Mann G, Patel M. The role of personalized choice: a randomized controlled trial of an online decision aid for prostate cancer screening. The Journal of Urology. 2013;189(4):e511.
81 Sawka AM, Straus S, Rotstein L, et al. Randomized controlled trial of a computerized decision aid on adjuvant radioactive iodine treatment for patients with early-stage papillary thyroid cancer. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Aug. 10. 2012;30(23):2906-2911. [pmid: 22753906].
82 Schroy PC 3rd, Emmons K, Peters E, et al. The impact of a novel computer-based decision aid on shared decision making for colorectal cancer screening: a randomized trial. Medical decision making: an international journal of the Society for Medical Decision Making. Jan-Feb. 2011;31(1):93-107. [pmid: 20484090].
83 Schroy PC 3rd, Emmons KM, Peters E, et al. Aid-assisted decision making and colorectal cancer screening: a randomized controlled trial. American journal of preventive medicine. Dec. 2012;43(6):573-583. [pmid: 23159252].
84 Schwartz MD, Valdimarsdottir HB, DeMarco TA, et al. Randomized trial of a decision aid for BRCA1/BRCA2 mutation carriers: impact on measures of decision making and satisfaction. Health psychology: official journal of the Division of Health Psychology, American Psychological Association. Jan. 2009;28(1):11-19.
85 Sheridan SL, Golin C, Bunton A, et al. Shared decision making for prostate cancer screening: the results of a combined analysis of two practice-based randomized controlled trials. BMC medical informatics and decision making. 2012;12:130. [pmid: 23148458].
86 Siminoff LA, Gordon NH, Silverman P, Budd T, Ravdin PM. A decision aid to assist in adjuvant therapy choices for breast cancer. Psycho-oncology. Nov. 2006;15(11):1001-1013. [pmid: 16511899].
87 Smith SK, Trevena L, Simpson JM, Barratt A, Nutbeam D, McCaffery KJ. A decision aid to support informed choices about bowel cancer screening among adults with low education: randomised controlled trial. BMJ. 2010;341:c5370. [pmid: 20978060].
88 Stephens RL, Xu Y, Volk RJ, et al. Influence of a patient decision aid on decisional conflict related to PSA testing: a structural equation model. Health psychology: official journal of the Division of Health Psychology, American Psychological Association. Nov. 2008;27(6):711-721.
89 Street RL Jr., Voigt B, Geyer C Jr., Manning T, Swanson GP. Increasing patient involvement in choosing treatment for early breast cancer. Cancer. Dec. 1. 1995;76(11):2275-2285. [pmid: 8635032].
90 Taylor KL, Williams RM, Davis K, et al. Decision Making in Prostate Cancer Screening Using Decision Aids vs Usual Care: A Randomized Clinical Trial. JAMA internal medicine. Jul. 29. 2013.
91 Tiller K, Meiser B, Gaff C, et al. A randomized controlled trial of a decision aid for women at increased risk of ovarian cancer. Medical decision making: an international journal of the Society for Medical Decision Making. Jul-Aug. 2006;26(4):360-372. [pmid: 16855125].
92 Trevena LJ, Irwig L, Barratt A. Randomized trial of a self-administered decision aid for colorectal cancer screening. Journal of medical screening. 2008;15(2):76-82. [pmid: 18573775].
93 van Roosmalen MS, Stalmeier PF, Verhoef LC, et al. Randomized trial of a shared decision-making intervention consisting of trade-offs and individualized treatment information for BRCA1/2 mutation carriers. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Aug. 15. 2004;22(16):3293-3301. [pmid: 15310772].
94 van Tol-Geerdink JJ, Willem Leer J, Weijerman PC, et al. Choice between prostatectomy and radiotherapy when men are eligible for both: a randomized controlled trial of usual care vs decision aid. BJU international. Apr. 2013;111(4):564-573. [pmid: 22882966].
95 Vodermaier A, Caspari C, Koehm J, Kahlert S, Ditsch N, Untch M. Contextual factors in shared decision making: a randomised controlled trial in women with a strong suspicion of breast cancer. British journal of cancer. Feb. 24. 2009;100(4):590-597. [pmid: 19209172].
96 Vodermaier A, Caspari C, Wang L, Koehm J, Ditsch N, Untch M. How and for whom are decision aids effective? Long-term psychological outcome of a randomized controlled trial in women with newly diagnosed breast cancer. Health psychology: official journal of the Division of Health Psychology, American Psychological Association. Jan. 2011;30(1):12-19.
97 Volk RJ, Cass AR, Spann SJ. A randomized controlled trial of shared decision making for prostate cancer screening. Archives of family medicine. Jul-Aug. 1999;8(4):333-340. [pmid: 10418541].
98 Volk RJ, Jibaja-Weiss ML, Hawley ST, et al. Entertainment education for prostate cancer screening: a randomized trial among primary care patients with low health literacy. Patient education and counseling. Dec. 2008;73(3):482-489. [pmid: 18760888].
99 Volk RJ, Spann SJ, Cass AR, Hawley ST. Patient education for informed decision making about prostate cancer screening: a randomized controlled trial with 1-year follow-up. Annals of family medicine. May-Jun. 2003;1(1):22-28. [pmid: 15043176].
100 Wakefield CE, Meiser B, Homewood J, et al. A randomized controlled trial of a decision aid for women considering genetic testing for breast and ovarian cancer risk. Breast cancer research and treatment. Jan. 2008;107(2):289-301. [pmid: 17333332].
101 Wakefield CE, Meiser B, Homewood J, et al. A randomized trial of a breast/ovarian cancer genetic testing decision aid used as a communication aid during genetic counseling. Psycho-oncology. Aug. 2008;17(8):844-854. [pmid: 18613319].
102 Wakefield CE, Meiser B, Homewood J, Ward R, O'Donnell S, Kirk J. Randomized trial of a decision aid for individuals considering genetic testing for hereditary nonpolyposis colorectal cancer risk. Cancer. Sep. 1. 2008;113(5):956-965. [pmid: 18618513].
103 Watson E, Hewitson P, Brett J, et al. Informed decision making and prostate specific antigen (PSA) testing for prostate cancer: a randomised controlled trial exploring the impact of a brief patient decision aid on men's knowledge, attitudes and intention to be tested. Patient education and counseling. Nov. 2006;63(3):367-379. [pmid: 16875796].
104 Whelan T, Levine M, Willan A, et al. Effect of a decision aid on knowledge and treatment decision making for breast cancer surgery: a randomized trial. JAMA: the journal of the American Medical Association. Jul. 28. 2004;292(4):435-441.
105 Whelan T, Sawka C, Levine M, et al. Helping patients make informed choices: a randomized trial of a decision aid for adjuvant chemotherapy in lymph node-negative breast cancer. Journal of the National Cancer Institute. Apr. 16. 2003;95(8):581-587. [pmid: 12697850].
106 Wilkes MS, Day FC, Srinivasan M, et al. Pairing physician education with patient activation to improve shared decisions in prostate cancer screening: a cluster randomized controlled trial. Annals of family medicine. Jul-Aug. 2013;11(4):324-334. [pmid: 23835818].
107 Williams RM, Davis KM, Luta G, et al. Fostering informed decisions: a randomized controlled trial assessing the impact of a decision aid among men registered to undergo mass screening for prostate cancer. Patient education and counseling. Jun. 2013;91(3):329-336. [pmid: 23357414].
108 Watts KJ, Meiser B, Wakefield CE, et al. Online prostate cancer screening decision aid for at-risk men: A randomized trial. Health psychology: official journal of the Division of Health Psychology, American Psychological Association. Sep. 2014;33(9):986-997.
109 Gattellari M, Donnelly N, Taylor N, Meerkin M, Hirst G, Ward JE. Does ‘peer coaching’ increase GP capacity to promote informed decision making about PSA screening? A cluster randomised trial. Family practice. Jun. 2005;22(3):253-265. [pmid: 15824055].
110 Lin GA, Halley M, Rendle KA, et al. An effort to spread decision aids in five California primary care practices yielded low distribution, highlighting hurdles. Health Aff (Millwood). Feb. 2013;32(2):311-320. [pmid: 23381524].
111 Feng B, Srinivasan M, Hoffman JR, et al. Physician communication regarding prostate cancer screening: analysis of unannounced standardized patient visits. Annals of family medicine. Jul-Aug. 2013;11(4):315-323. [pmid: 23835817].
112 Bryan T, Snyder E, Estrada C, Castiglioni A. Education in delivering patient-centered care: Provider comfort level in counseling women ages 40-49 regarding breast cancer. J Investig Med. 2013;61(2):524.
113 Uy V, May SG, Tietbohl C, Frosch DL. Barriers and facilitators to routine distribution of patient decision support interventions: a preliminary study in community-based primary care settings. Health expectations: an international journal of public participation in health care and health policy. Jun. 2014;17(3):353-364. [pmid: 22212453].
114 Cohen J. Statistical power analysis for the behavioral sciences. Hillsdale, NJ. Erlbaum Associates. 1988.
115 Kruger J, Dunning D. Unskilled and unaware of it: how difficulties in recognizing one's own incompetence lead to inflated self-assessments. Journal of personality and social psychology. Dec. 1999;77(6):1121-1134. [pmid: 10626367].
116 Sepucha KR, Fowler FJ Jr., Mulley AG Jr. Policy support for patient-centered care: the need for measurable improvements in decision quality. Health Aff (Millwood). 2004. Suppl Variation: VAR54-62.
117 Clark JA, Wray N, Brody B, Ashton C, Giesler B, Watkins H. Dimensions of quality of life expressed by men treated for metastatic prostate cancer. Social science & medicine. Oct. 1997;45(8):1299-1309. [pmid: 9381242].
118 Gentles SJ, Stacey D, Bennett C, Alshurafa M, Walter SD. Factors explaining the heterogeneity of effects of patient decision aids on knowledge of outcome probabilities: a systematic review sub-analysis. Systematic reviews. 2013;2:95. [pmid: 24143875].
119 Coyne I, O'Mathuna DP, Gibson F, Shields L, Sheaf G. Interventions for promoting participation in shared decision-making for children with cancer. The Cochrane database of systematic reviews. 2013;6. CD008970.
120 Joseph-Williams N, Elwyn G, Edwards A. Knowledge is not power for patients: a systematic review and thematic synthesis of patient-reported barriers and facilitators to shared decision making. Patient education and counseling. Mar. 2014;94(3):291-309. [pmid: 24305642].
121 Bekker HL, Legare F, Stacey D, O'Connor A, Lemyre L. Is anxiety a suitable measure of decision aid effectiveness: a systematic review?. Patient education and counseling. Jul. 2003;50(3):255-262. [pmid: 12900095].
122 Carpenter JS, Studts JL, Byrne MM. A systematic review of menopausal symptom management decision aid trials. Maturitas. May. 2011;69(1):11-21. [pmid: 21367544].
123 Dugas M, Shorten A, Dube E, Wassef M, Bujold E, Chaillet N. Decision aid tools to support women's decision making in pregnancy and birth: a systematic review and meta-analysis. Social science & medicine. Jun. 2012;74(12):1968-1978. [pmid: 22475401].
124 Evans R, Edwards A, Brett J, et al. Reduction in uptake of PSA tests following decision aids: systematic review of current aids and their evaluations. Patient education and counseling. Jul. 2005;58(1):13-26. [pmid: 15950832].
125 Flynn D, Knoedler MA, Hess EP, et al. Engaging patients in health care decisions in the emergency department through shared decision-making: a systematic review. Academic emergency medicine: official journal of the Society for Academic Emergency Medicine. Aug. 2012;19(8):959-967. [pmid: 22853804].
126 Harun A, Harrison JD, Young JM. Interventions to improve patient participation in the treatment process for culturally and linguistically diverse people with cancer: a systematic review. Asia-Pacific journal of clinical oncology. Jun. 2013;9(2):99-109. [pmid: 22897920].
127 Khunpradit S, Tavender E, Lumbiganon P, Laopaiboon M, Wasiak J, Gruen RL. Non-clinical interventions for reducing unnecessary caesarean section. The Cochrane database of systematic reviews. 2011;(6). CD005528.
128 Meilleur KG, Littleton-Kearney MT. Interventions to improve patient education regarding multifactorial genetic conditions: a systematic review. American journal of medical genetics. Part A. Feb. 15. 2009;149A(4):819-830. [pmid: 19291763].
129 O'Connor AM, Bennett C, Stacey D, et al. Do patient decision aids meet effectiveness criteria of the international patient decision aid standards collaboration? A systematic review and meta-analysis. Medical decision making: an international journal of the Society for Medical Decision Making. Sep-Oct. 2007;27(5):554-574. [pmid: 17873255].
130 O'Connor AM, Bennett CL, Stacey D, et al. Decision aids for people facing health treatment or screening decisions. The Cochrane database of systematic reviews. 2009;(3). CD001431.
131 Simon EE, Merli C, Herndon J, Hamm LL. Contribution of luminal ammoniagenesis to proximal tubule ammonia appearance in the rat. The American journal of physiology. Sep. 1990;259(3 Pt 2):F402-407. [pmid: 1975733].
132 Thomson MD, Hoffman-Goetz L. Readability and cultural sensitivity of web-based patient decision aids for cancer screening and treatment: a systematic review. Medical informatics and the Internet in medicine. Dec. 2007;32(4):263-286. [pmid: 18072004].
133 Vlemmix F, Warendorf JK, Rosman AN, et al. Decision aids to improve informed decision-making in pregnancy care: a systematic review. BJOG: an international journal of obstetrics and gynaecology. Feb. 2013;120(3):257-266. [pmid: 23145991].
134 Waljee JF, Rogers MA, Alderman AK. Decision aids and breast cancer: do they influence choice for surgery and knowledge of treatment options?. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Mar. 20. 2007;25(9):1067-1073. [pmid: 17369570].
135 Williams L, Jones W, Elwyn G, Edwards A. Interactive patient decision aids for women facing genetic testing for familial breast cancer: a systematic web and literature review. Journal of evaluation in clinical practice. Feb. 2008;14(1):70-74. [pmid: 18211647].