# Methods

The protocol for the systematic review was prospectively registered with the international prospective register of systematic reviews (PROSPERO – registration number CRD42013006197) and was informed by discussions with the technical experts listed in the beginning of this document over a series of teleconferences. The reporting of this systematic review follows the PRISMA guidelines.15 A Task Order Officer (TOO) with the Agency for Healthcare Research and Quality (AHRQ) oversaw the progress of the project, facilitated a common understanding among all parties involved in the project, and reviewed the report for consistency, clarity, and to ensure that it meets AHRQ standards. The TOO was asked for input, but did not make decisions in the design of the project or its conduct and had no part in the drafting of the report.

## Eligible Studies for Key Question 1

We included randomized controlled trials comparing use of patient decision aids with other patient decision aids or with no decision aid intervention. We included trials of mature patient decision aids delivered at the point of the actual decision. We excluded trials about hypothetical treatment decisions. For example, we excluded hypothetical questions about early cancer treatment in people not yet diagnosed with cancer, or trials about cancer screening among people who would not be typical screening candidates.

We predefined three populations of interest, based on risk or presence of cancer. The first population included people without cancer who are at average risk and face decisions about cancer screening (whether or how to be screened). The second population included people without cancer but with high risk of cancer, e.g., because they are suspected or known to have a hereditary cancer-related condition, such as the Lynch or von Hippel-Lindau syndromes, or are carriers of deleterious BRCA gene mutations. This group may face decisions about further diagnostic workup or about undergoing preventive interventions. The third population included patients diagnosed with early cancer, defined as being at a stage with favorable prognosis (typically local disease only) and where interventions have curative intent (e.g., stage IIa or lower for prostate cancer). We accepted the individual study claims for the definition of early cancer. When a study used an alternative cancer staging, we adjudicated an early cancer stage using information for the National Cancer Institute site. We included only studies in people who were legally able to make decisions for themselves or an underage minor.

We followed the IPDAS collaboration and previous systematic reviews in defining decision aid-based interventions as, at a minimum, (1) informing about available options and the expected associated benefits and harms, and (2) incorporating at least implicit clarification of the decisionmaker's values.3,4

## Eligible Studies for Key Question 2

For the second Key Question, we included comparative studies informing on the effectiveness of interventions for promoting shared decision making to providers caring for the populations discussed for the first Key Question, specifically provider-targeted interventions to increase shared decision making with the use or increased use of a decision aid. Because so few studies have been done on this topic, eligible designs included randomized and cluster-randomized trials, nonrandomized studies with concurrent comparators, before-after studies, and interrupted time series studies.

## Outcomes

We specified outcomes of interest prospectively in the review protocol. Almost by definition, for most situations for which patient decision aids are proposed, the likelihood of mortality or other hard clinical outcomes across the compared options is either known to be similar or is substantially uncertain. Because no single optimal choice exists, hard clinical outcomes are probably not particularly relevant for measuring the effectiveness of decision-aid-based interventions. Intermediate health outcomes, such as quality of life, anxiety, depression, or decisional regret, are more relevant measures of the effects of decision-aid-based interventions. We organized outcomes in four groups:

- Outcomes related to measurements of decisional quality and cognition included differences in knowledge scores (about the condition, options, or expected outcomes as defined in each study); number of people making informed choices (people who have adequate knowledge and make a choice); congruence between actual choices and patient values; and number of people with accurate perception of their personal cancer risk.
- Outcomes related to attributes of the decision-making process included differences in the total score on the Decisional Conflict Scale (DCS);16 patient, provider or third-party-rated quality of communication (as defined by authors); patient participation in decision making; proportion of undecided patients; patient satisfaction with the decision-making process; and intended choices and adherence to them.
- Outcomes related to affect, emotion, and quality of life included differences in the state or total scores of the State-Trait Anxiety Inventory (STAI, short or full version);17,18 the Hospital Anxiety and Depression Scale (HADS);19 quality of life Short Form (SF) 6-, 12-, or 36-item questionnaires;20 the Impact of Event Scale (IES, for emotional distress);21 and the Decision Regret Scale (DRS).22
- Finally, process and system-level outcomes included differences in resource use and valuations thereof, consultation length, and litigation rates.

Table 1 includes brief descriptions of selected instruments, along with comments on the interpretation of the magnitude of differences.

Table 1 Descriptions of selected instruments and minimal important differences (known or assumed)

Outcome Category, Instrument | Description | Minimal Important Difference
Attributes of decision-making process
Decisional conflict scale – DCS16 | Five subscales measuring perceptions of uncertainty in choosing options, modifiable factors (e.g., feeling informed, having unclear values), and effective decision making. We are using the total score adjusted to a scale of 0 (least conflicted) through 100 (most conflicted). | It is unclear what the minimal important difference is. The DCS manual suggests powering studies for an effect size of 0.3, and we use this as a proxy of the minimal important difference. Also often reported as a threshold or percentage who score below 25 with no available consensus on reporting. The effect size corresponds to a difference of 5 in the 0 to 100 scale, using a standard deviation of 15 units (median in observed studies).
Affect, emotion and quality of life
State-Trait Anxiety Inventory – STAI17,18 | 20 questions on anxiety state, and 20 on trait. Results translated to a scale from 20 (least anxious) to 80 (most anxious). We use results for state, or for the total score. | We found no information on the minimal important difference. We operationally define it as difference bigger than 20 units, based on the scale range of 20-80.
Hospital Anxiety and Depression Scale – HADS19 | Measures anxiety and depression domains, over a 0 (least) through 21 (most) scale for each domain. We are interested in the individual domains and the total score. | We found no information on the minimal important difference. We operationally define it as difference bigger than 5 on a 0-21 range (per domain) or bigger than 10 on a 0 to 42 range (total).
Short form (SF) 6, 12 or 36^20^ | Multi-purpose short form health survey covering 8 domains. Results translated to a Likert scale from 0 (worse) to 5 (best). We are interested in the mental health or the general health domain. | The minimal important difference is 1 unit in the 0-5 range.
Impact Event Scale – IES21 | Measures subjective response to a traumatic event in intrusion and avoidance domains. Expressed in 0 (least impactful) to 1 (most impactful). We are interested in the total scale. | We found no information on the minimal important difference. We operationally define it as difference bigger than 0.25, based on the scale range of 0-1.
Decision Regret Scale – DRS22 | Measures distress or remorse after a healthcare decision using 5 questions. Scores expressed in 0 (no regret) to 100 scale (most regret). | We found no information on the minimal important difference. We operationally define it as difference bigger than 25 units, based on the scale range of 0-100.

## Study Identification

We searched MEDLINE, EMBASE, the Cochrane Central Register of Controlled Trials (CENTRAL), PsycINFO, and the Cumulative Index to Nursing and Allied Health Literature (CINAHL) from inception to June, 2014, using two separate strategies, one for each Key Question. The strategies were based on previous Cochrane reviews,4 13 and are reported in Appendix A. We also perused the references included in other systematic reviews4-8 and in included studies. We screened citations for eligibility using the open-source abstrackr software (accessible at www.cebm.brown.edu/software).23 To ensure consistency, all five reviewers performed a calibration exercise and screened the first 200 citations, in two rounds of 100 citations each, using broad inclusion criteria. Disagreements were discussed and analyzed to clarify screening criteria. Once it was deemed that all reviewers were applying the criteria in the same way, we continued with single screening of the remaining abstracts. All included papers were assessed for eligibility by two reviewers. Conflicts and questions were resolved by discussion with a third reviewer. In screening the full text papers, we identified trials with multiple reports, based on explicit references to other eligible papers and the enrollment sites and periods and numbers randomized. In order to capture sequential collaborative efforts, we paid attention to groups of reports that had at least half or at least three authors in common.

## Data Extraction

We used the Systematic Review Data Repository (SRDR) to extract data from each study.24,25 Extracted data are publicly available at http://srdr.ahrq.gov/projects/143 (last accessed October 12, 2014). Extraction forms were specific to each Key Question and are also available in SRDR. Briefly, for each eligible study we extracted information from one or more associated articles about: (1) the citation; (2) the population (including baseline risk of cancer or cancer stage); (3) the delivery format or formats (printed, audio or video material not on a computer, computer software, Web site, in-person delivery with a person providing logistical help, use of support groups or patient navigators, decision board/option grid), and content (explicit elicitation of values, e.g., by quantifying preferences on a scale, vs. implicit elicitation of values, e.g., through discussion of what people often care about; generic vs. personalized probabilities; others' opinions; human coaching in decision making; non-human-mediated guidance in decision making; decision analysis model) and other attributes of the intervention (e.g., whether it was developed based on theory; was tailored to the populations' health or numerical literacy, language, or culture; needing a human to deliver or to support logistically; used by patient, or both patient and provider; included support group or navigator); (4) definitions of outcomes and outcome-related results; (5) and risk-of-bias-related items (see below). As needed, we back-calculated numbers for quantitative synthesis from graphs or other reported numerical information. We imputed missing standard deviations as the median standard deviation in less than eight percent of arms. Information on the characteristics of the decision aids and numerical information was extracted or cross-checked at least twice. If that information was not in the paper, we attempted to access the original decision aid or other studies of that decision aid for this information.

## Data Synthesis and Exploration of Heterogeneity

For both Key Questions, we first synthesized the results qualitatively. We used sliding mean graphs to depict the evolution of decision aid formats and contents over time. Our main analyses used hierarchical (random effects) regression models adjusted for population group (average risk, high risk, early cancer) and additional intervention characteristics. These models can be difficult to fit with few studies. Thus we ran analyses in outcomes with at least 10 trials overall and with at least 2 trials in each population group. We used hierarchical random effects meta-regression analyses to examine associations between the outcomes in each arm, as well as study-level and arm-level characteristics. See Appendix B for an explicit description of the meta-analysis model.

We assessed effect modification as interaction term with the variable corresponding to the decision aid intervention. We examined a priori-defined effect modification for each population group (screening, high risk, early cancer), and for delivery formats, content, other attributes of the decision aid (whether it was tailored to target population, such as low literacy, or used by consumer and provider together or by the consumer only), and study design items (generation of the randomized sequence, blinding of participants and outcome assessors, allocation concealment, and loss to follow-up smaller than 20 percent).

## Sensitivity Analyses

The recent update of the Cochrane review (current as of 2012) included a subset of the trials identified in the current report (see Appendix C for a description of the discrepancy which is mainly because of our including more recent literature). To facilitate comparisons with the conclusions of the Cochrane review, which used different analyses, we repeated all analyses for subset of trials included in the Cochrane review.

In addition, we ran sensitivity analyses, including results from trials with incompletely reported results after making assumptions of borderline plausibility, and we checked the robustness of results by imputing 1.20 or 0.80 times the median standard deviation value when this was missing. We also examined alternative priors for model parameters. Results of sensitivity analyses were similar to those of the main analyses and are not shown.

## Risk of Bias in Individual Studies and Strength of the Evidence Base

We used the assessment methods for assessing risk of bias in individual studies and the strength of evidence for each outcome across the evidence base detailed in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews.26 There are numerous, different study characteristics that may introduce bias in clinical trials; several of these characteristics are domain specific. We have explicitly evaluated risk of selection, performance, attrition, detection, and selective outcome reporting biases. The strength of the available evidence for each outcome was assessed for the body of evidence using four strength of evidence levels: high, moderate, low, and insufficient.26 These describe our level of confidence that the evidence reflects the true effect for the major comparisons of interest.