# Key Questions

Two Key Questions formalize the aims of this work. They were developed over a stakeholder-driven and publicly reviewed topic development and refinement process.12,14

The first Key Question pertains to interventions targeting health care consumers who face decisions about cancer screening and prevention or treatment. It asks: how do interventions that incorporate patient decision aids compare with each other or with interventions that do not include decisions aids with respect to measurements of decision quality, characteristics of the decision-making process, choices and adherence to choices, health outcomes, and health care–system outcomes? For example, does the use of a decision aid--compared with standard care--affect screening behavior in women facing the decision to continue mammography (and at which time intervals) or not?

The second Key Question pertains to interventions targeting providers who care for consumers facing decisions relevant to cancer screening or early cancer. It asks: how do these interventions compare with each other or with no intervention with respect to likelihood of engaging in shared decision making, as well as to the outcomes mentioned in the first Key Question? For example, compared with no training, does training of providers in shared decision making affect the willingness of providers to engage in shared decision making?

For both Key Questions, a central component was the analysis of effect modifiers related to the characteristics of the populations and the attributes of the interventions, as detailed in the Methods section.