# Introduction

Many health care decisions involve uncertainty due to the lack of robust evidence or tradeoffs between the expected benefits and harms.^a^ For such decisions no universally optimal choice exists, because people differ in their attitudes towards risk and how they value outcomes.1,2 Some decisions about screening for cancer or management of early cancer are examples of value-laden decisions: The available options have comparable or uncertain effects on mortality or disease progression, so that other outcomes take the forefront in the decision-making process.

a For example, while it is clear that a person with bacterial pneumonia should receive antibiotics, it is not clear whether a 55-year-old man with low grade early prostate cancer should undergo surgery or proceed with watchful waiting. For this cancer patient, uncertanty exists about the difference in the probability of long term survival or cancer progession with the various options. Further, because options have different risks of adverse outcomes (e.g., incontinence, sexual dysfunction, worry), they are value-sensitive.

Patient decision aids have been developed to help health care consumers and their providers identify the available alternatives and choose the one that aligns with their values. They are used to supplement the interaction between patients and providers and promote shared decision making.3,4 According to the International Patient Decision Aid Standards (IPDAS) collaboration, a decision aid helps the patient recognize that a decision is to be made, provides information about the available options and their expected benefits and harms, and, in some fashion, helps consumers (patients) clarify their risk attitudes or preferences about possible outcomes.3

A Cochrane review has summarized the evidence on the effectiveness of patient decision aids across malignant and nonmalignant conditions,4 and concluded that, across all examined populations and decision aid formats and contents, using decision aids increases knowledge about options and expected benefits and harms and results in an improved congruence between choices and values. Other published research where such evidence for cancers was systematically reviewed5-8 reached similar conclusions.

However, it is still unclear whether the effectiveness of patient decision aids for decisions related to cancers differs by peoples' average risk of cancer, their health literacy and numeracy, or by the specific attributes of the decision aid-based intervention. For example, research suggests that patients' baseline understanding of issues in cancer screening may affect whether they ultimately made an informed and considered choice,9,10 and that patients' perception of their own risk was an important predictor of cancer screening uptake.11 Such information is important for developing practical guidance about designing and using decision aids, particularly for decisions related to screening, prevention, or treatment of early cancers, the target population for this review.12

We triangulated the importance of these issues by engaging a diverse panel of stakeholders, including developers and users of patient decision aids, representatives of professional societies, patient advocates and non-syndicated patients, representing the review's intended audiences. The panel agreed that this review's target population should include not only patients with early cancer, but also patients who are either at high risk of cancer or are at average risk and are deciding whether to be screened. These populations can be examined in aggregate because the types of decisions being made are similarly equivocal in terms of both benefits and harms. Further, the panel also agreed that provider willingness to engage in shared decision making with decision aids is a prerequisite for patient use of decision aids outside the experimental setting of a trial. A Cochrane systematic review summarized evidence on the effectiveness of any intervention to increase the uptake of shared decision making by health professionals through 2009, and concluded that healthcare professional training and use of decision aids may be important.13 The current systematic review is designed to address issues relating to content and format of patient decision aids in terms of their intended audiences, as well as factors related to provider utilization.