# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Peter Albertsen, M.D.
  American Urological Association
  Farmington, CT
- Jonathan Cosin, M.D.
  Society of Gynecologic Oncology
  Plainville, CT
- James Dolan, M.D.
  University of Rochester
  Rochester, NY
- Rochelle Fu, Ph.D.
  Oregon Health & Science University
  Portland, OR
- Michel Labrecque, M.D., Ph.D., C.C.M.F., FCMF
  Laval University
  Quebec, Canada
- Melissa R. Partin, Ph.D.
  Department of Veterans Affairs
  Minneapolis, MN
- Karen Sepucha, Ph.D.
  Harvard University
  Cambridge, MA
- Dirk Ubbink, M.D., Ph.D.
  Academic Medical Center at the University of Amsterdam
  Amsterdam, Netherlands
- Trudy van der Weijden, M.D., Ph.D.
  Maastricht University
  Maastricht, Netherlands
- Robert Volk, Ph.D.
  MD Anderson Cancer Center
  Houston, TX