# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Peter Albertsen, M.D.
  American Urological Association
  Farmington, CT
- Otis Brawley, M.D.
  American Cancer Society
  Atlanta, GA
- Jonathan Cosin, M.D.
  Society of Gynecologic Oncology
  Plainville, CT
- Michael Danso, M.D.
  American Society for Clinical Oncology
  Norfolk, VA
- David Penson, M.D.
  Vanderbilt University
  Nashville, TN
- Marilyn Schapira, M.D., M.P.H.
  University of Pennsylvania
  Philadelphia, PA
- Karen Sepucha, Ph.D.
  Harvard University
  Cambridge, MA
- Trudy van der Weijden, M.D., Ph.D.
  Maastricht University
  Maastricht, Netherlands