# Acknowledgments

We are thankful to Maria Christou for her help in doublechecking descriptive data entered in the Systematic Review Data Repository and to professors Dawn Stacey at the University of Ottawa, Ontario, Canada, and France Légaré at Laval University, Quebec, Canada, for their comments on an earlier version of this report.