# Discussion

## Overall Summary and Strength of Evidence

We systematically appraised the efficacy of decision aids in 68 published randomized controlled trials with over 25,000 participants facing a cancer screening or early-cancer treatment decision. The assessed decision aids were considerably diverse in terms of delivery format, content, context and theoretical background, which often made synthesis a challenge. Considerable diversity was also observed with regards to the type of decision and the outcomes assessed.

In sum, we found that decision aids increase knowledge without adverse impact on decisional conflict, anxiety, or possibly depression. There were indications that patients using decision aids are more likely to make informed decisions and have accurate risk perceptions, and further, may make choices that best agree with their values, and may be less likely to remain undecided. There was insufficient, sparse or no information about effects of decision aids on patient-provider communication, patient satisfaction with the decision-making process, resource use, consultation length, costs, or litigation rates. The effectiveness of decision aids did not appear to be modified by differences in the population (general risk of cancer, high risk of cancer, or early cancer), delivery format, their content, or other attributes of their development and implementation. For knowledge and decisional conflict outcomes, the credible intervals for effect modification were wide and small to moderate differences could not be excluded. No clinically important differences were observed for anxiety. Finally, for Key Question 2, very limited information was available on the effectiveness of interventions that target providers to promote shared decision making. Table 6 summarizes the dispositions of the review team about the strength of the evidence base with respect to the Key Questions. Methodological characteristics of the individual trials are listed in Appendix G. A more detailed description of the strength of the evidence per population group, outcome category and comparison is in Appendix H.

Table 6 Summary of conclusions and associated strength of evidence dispositions

Conclusion | Strength of Evidence | Comments
Key Question 1- effectiveness of using vs. not using DAs
Using DAs increases knowledge without adverse impact on decisional conflict or anxiety | - High (knowledge, anxiety); - Moderate (decisional conflict) | Quantitative analyses per outcome; - Knowledge, SMD: 0.23 (0.09, 0.35); - Decisional Conflict Scale, WMD: -5.3 (-8.9, -1.8) on 0-100 scale; - State Trait Anxiety Inventory, WMD: 0.1 (-1.0, 0.7) on 20-80 scale
Using DAs results in more accurate risk perception, informed decisions | Low | - Limited number of studies (less than 9, out of a total 68), each using different outcome definitions; - No quantitative synthesis done
Using DAs has no adverse effects on depression | Low | [As above]
Using DAs may result in better congruence between choices and values, and may reduce proportion of undecided patients | Low | [As above]
The DA effect on patient-provider communication, or patient satisfaction with decision-making process, or resource use, or consultation length, or costs, or litigation rates is unknown | [Insufficient] | [As above]
DA efficacy does not vary across populations by risk/presence of cancer for knowledge, decisional conflict, anxiety | - Moderate | - For knowledge and decisional conflict, the width of 95% CrI cannot exclude potentially important effect modification; - For anxiety, the width of 95% CrI for the differences excludes substantial effect modification, but there are relatively few studies per subgroup
[Varying DA efficacy for other outcomes is unknown] | [Insufficient] | - Limited number of studies
Key Question 1 - Comparative effectiveness of different DAs by delivery formats, content and other attributes *
There are no differences in efficacy between different DAs knowledge, decisional conflict, and anxiety | Low | - Results from hierarchical meta-regression; - Wide 95% CrI cannot exclude potentially important effect modification for knowledge or decisional conflict; - Based on 95% CrI width, clinically meaningful effect modification for anxiety is unlikely
[The DA effect modification for other outcomes is unknown] | Not rated | - Limited number of studies (between 0 and 9, out of a total 68), each using different outcome definitions; - Cannot assess effect modification by factors; - No quantitative synthesis done
Key Question 2 – Effectiveness of interventions to promote shared decision making through Das
[Insufficient information to draw conclusions] | [Insufficient] | - No data on most outcomes/ limited evidence base

* Formats = Audiovisual material, software or website, printed material, in-person education, option grid, decision board.

Content = Explicit values clarification, probability of outcomes (generic), probability of outcomes (personalized), others' opinions, coaching in decision making (human mediated), guidance in decision making (non-human-mediated), decision analytic model.

Other attributes = Developed based on theory, needing a human to deliver, having both explicit clarification of values and presenting personalized probabilities of outcomes, being personalized to patient, tailored to target population, used by patient and provider, used by patient only, includes human for logistical support, includes support group, includes patient navigator.

CrI = credible interval; DA = decision analysis; SMD = standardized mean difference; WMD = weighted mean difference.

Arguably, decision aids would be most needed in vulnerable populations, including people with low literacy or numeracy, limited educational attainment, challenged socioeconomic status, or hindered by language and cultural barriers.118 A proportion of trials evaluated decision aids tailored to a vulnerable population (n=19 of 68). However, there was no evidence for difference in the effectiveness of decision aids in them (Tables 3, 4 and 5).

We found few or no trials for decisions relevant to malignancies other than breast, prostate and, to a lesser extent, colorectal cancer. Similar to observations from a Cochrane review on shared decision making for pediatric malignancies,119 we found no trials in guardians of children with malignancy. Therefore as decision aids are developed for other common cancers such as lung, bladder, uterus/cervix, skin (melanoma), pancreas, and thyroid cancers, or leukemias, it will be important to evaluate whether they have similar effectiveness as in the better-studied cancers.

We examined several characteristics of decision aid-based interventions to capture how elaborate they are, in terms of their delivery formats, the personnel necessary to administer them, how they are used (by the participant alone, or in conjunction with a provider), and what information they contain. Perhaps contrary to expectations,4 we found no evidence for differences in the effectiveness between decision aids that are more or less elaborate in terms of personalized probabilities of events, involve humans in their delivery, and so on. This lack of effect modification might suggest that a large part of the benefits of decision aids are mediated by indirect mechanisms, e.g., perhaps through stimulating question-asking -and thus knowledge enhancement- and information solicitation on behalf of the patient which facilitates power attainment.120

In the eligible trials, very few decision aids were reported to have been developed based on psychological theory, and therefore, it was not possible to detect whether they had different effects from other decision aids. We did not attempt to map trial results on theoretical models about mechanisms through which decision aids can affect outcomes. Such an endeavor, perhaps through a path analysis or a mediation analysis, might help identify the theoretical models that best fit the empirical data, and provide explanations of why and how decision aids work. We cannot comment on the feasibility of such an effort. Even with appropriate individual patient data, it would be a tall order. Further, such an analysis would interject extra-evidentiary information (through the structure of the theorized model itself), and should probably be treated as a hypothesis-forming one. The difficulties of undertaking such an analysis may be exposed with a simple example: We found evidence that decisional conflict (at the shortest available followup) is somewhat lower with decision aids. However, one might theorize a transient increase in decisional conflict when using a decision aid, which would subsequently resolve when the decision is cognitively and emotionally processed. It is unclear whether this dissonance is a matter of timing (e.g., trial data were measured after the decisional conflict peaked in the decision aid arm, and during a rebound); whether the decisional conflict measurement instruments have a systematic bias; or whether such a theory is not supported by the data.

This literature has a proliferation of outcome measures. Figure 4 shows 15 categories of predefined outcomes, and trials used various definitions within each category. Developing good outcomes for the target concept of decisional quality as well as for the target of shared decision making happening is challenging,3 but necessary for measuring the effectiveness of decision aids and for learning from past empirical data.116 A major research goal should be to develop and promote a limited set of easily measurable and well-characterized outcomes of decisional quality. Further, if decision aids are to be used in routine care, in real-life settings, it is important to develop outcomes for monitoring their uptake, use and impact of decision aids at a systems level.13

Decision aids are complex interventions, and their successful integration and continued use in routine care depends on many factors, including patient and provider acceptance, system infrastructure, fit with other processes, and other factors only peripherally related to the patient-provider dyad. Thus, implementation of decision aids interventions in routine practice requires consideration of many additional factors. Although we looked for studies of the effectiveness of interventions to providers for promoting shared decision making through decision aids, we found limited evidence. A more general treatment of shared decision-making promotion interventions did not draw strong conclusions.13

Our findings are in accordance with previous efforts to summarize the evidence on the effectiveness of decision aids in general or for cancer in particular. Prior works concluded that decision aids increase knowledge; increase the likelihood of choosing a less invasive option (for surgical care decisions, and decisions related to treatment of breast cancer), and decrease in decisional conflict, without major adverse impact on anxiety, depression, quality of life, or emotional distress.4,121-135 These works focus on the overall effectiveness of decision aids, and secondarily, on how “simpler” decision aids compare with “more detailed” ones in head-to-head studies. The 2014 Cochrane review defined as “simpler” the decision aid version that had fewer components or less personalized information, and as “more detailed” the decision aid with the most components or the most personalized information. The review found some evidence that “more detailed” decision aids result in somewhat higher knowledge scores than “simpler” ones.4 However, this definition is subject to confounding by study, and results are difficult to interpret. For example, the “more detailed” decision aid in one trial can have fewer components than the “simpler” decision aid in another trial.

A contribution of our systematic review is that it explicitly examined differences in the effectiveness of decision aids by isolating attributes of their delivery format, content, and other factors, and found that the currently accumulated randomized evidence does not support an association between isolated attributes and decision aid effectiveness. Based on 95% credible intervals, none of the examined characteristics explained the effectiveness of decision aids. If there is indeed no difference between decision aids by the examined characteristics, simpler decision aids in terms of format, content or administration method (which might be less costly to develop and maintain, and easier to use) may be as effective as more elaborate ones.

## Methodological Challenges and Implications for Future Research

A most important methodological challenge is the lack of validation studies. Only eight of the assessed decision aids were validated in a second trial. In most cases, members of the same team, which typically includes the developers of the decision aid, conducted both trials. When independent replications do exist, one often cannot distinguish genuine replication from allegiance bias, where research conducted by allegiant teams may be more likely to replicate. Further, a decision aid might work better in the hands of the developers (and in the system in which it was developed) compared with an implementation in a new setting.

Decision aids should not be static, and should be kept current in terms of informational content and presentation and delivery formats. Decision aids that are one-off developments are likely to not be updated by their primary developers or by others. Thus one might consider investing in a generic, modular platform for developing and delivering decision aids. The platform could allow for modular expansion of the decision aid content (e.g., to add stories of other people facing a similar problem, or a value clarification exercise) or include web-based ones. It would facilitate development of decision aids by porting know-how in the technical aspects of the development across diseases; translation to other languages; and keeping decision aids current.

## Limitations

Some limitations of this review are inherited from the individual studies, and have been discussed in the paragraphs above. Additional limitations pertain to selection biases that affect the whole evidence base, including publication bias, and selective outcome or analysis reporting. When such biases operate the probability that a study (or an outcome or an analysis) is published (or reported in sufficient detail) is dependent on the findings. Typically, statistically significant studies or results are more likely to be published fully, compared with statistically nonsignificant ones. Thus, these biases can distort the summary of the evidence base. No mitigation for the effects of these biases is feasible, and perhaps the only practical approach is the one we took here: be exhaustive in the efforts to identify studies, run sensitivity analyses, and avoid untempered interpretations of the results.

Finally, clinical and especially shared decision making is such a complex phenomenon to execute, to influence and to measure that valuable information could also arise from other study designs such as observational studies and qualitative studies. The systematic appraisal of this kind of research goes beyond the scope of the present systematic review yet remains of great interest

## Conclusions

Cancer-related decision aids have evolved over time and there is considerable diversity in both format and available evidence. We found that cancer-related decision aids increase knowledge without adverse impact on decisional conflict, or anxiety with moderate to high strength of evidence. Patients using decision aids may be more likely to make informed decisions and have accurate risk perceptions, and further, may make choices that best agree with their values, and may be less likely to remain undecided.

This review adds to the literature that the effectiveness of cancer-related decision aids does not appear to be modified by specific attributes of decision aid delivery format, content, or other characteristics of their development and implementation. Very limited information was available on other outcomes or on the effectiveness of interventions that target providers to promote shared decision making by means of decision aids.