# Detailed Strength of Evidence Assessment Table

Table H1 Detailed strength of evidence assessment