# Abstraction of Information Related to Risk of Bias in Individual Studies

## Key Question 1

Table G1 Information related to risk of bias in individual studies for Key Question 1

First Author, Year (PMID) | Population/body system and decision type Decision Aid ID* | Low Risk of Bias due to Inadequate Randomized Sequence Generation | Low Risk of Bias due to Inadequate Allocation Concealment | Low Risk of Bias due to Inadequate Outcome Assessor Blinding | Low Risk of Bias due to Attrition (Attrition Rate below 20%)
| Screening
| Breast
Mathieu (2007) 17954796 | 3 | Yes | Yes | No | No
| Colorectal
Trevena (2008) 18573775 | 11 | Unclear | Yes | Yes | Unclear
Smith (2010) 20978060 | 11 | Yes | Yes | No | Yes
Schroy (2010) 20484090 | 9 | Unclear | Unclear | No | Unclear
Pignone (2000) 11085838 | 8 | Yes | Yes | Yes | No
Griffith (2008) 18218084 | 8 | Yes | Yes | Unclear | No
Miller (2011) 21565651 | 8 | Yes | Unclear | Unclear | No
Dolan (2002) 11958495 | | Yes | No | No | No
Ruffin (2007) 17689600 | | Yes | Yes | Yes | No
| Prostate
Volk (2008) 18760888 | 20 | Yes | Unclear | No | Yes
Taylor (2013) 23896732 | 10 | Yes | Unclear | Unclear | Unclear
Williams (2013) 23357414 | 10 | Unclear | Unclear | No | No
Stephens (2008) 19025266 | 7 | Yes^a^ | Yes | Yes | No
Myers (2005) 16173330 | 6 | Unclear | Unclear | No | No
Myers (2011) 20619576 | 6 | Unclear | Yes | No | Unclear
Frosch (2008) 18299490 | 5 | Yes | Yes | No | No
Frosch (2003) 14521639 | 4, 5 | Yes | Yes | No | Unclear
Volk (1999) 10418541 | 4 | Yes | Unclear | Unclear | No
Partin (2004) 15242468 | 2, 4 | Yes | Yes | Yes | No
Gattellari (2003) 12790313 | 1 | Yes | Unclear | No | Unclear
Gattellari (2005) 15911190 | 1 | Yes | Yes | No | No
Watson (2006) 16875796 | | Yes | Yes | Unclear | Unclear
Ilic (2008)18373146 | | Yes | Yes | No | No
Holt (2009) 19718941 | | Unclear | Unclear | No | Unclear
Allen (2010) 20716619 | | Yes | Unclear | Unclear | Unclear
Evans (2010) 20693148 | | Yes | Yes | No | Yes
Chan (2011) 21237611 | | Yes | Unclear | Unclear | No
Lepore (2012) 22825933 | | Yes | Yes | Unclear | No
Sheridan (2012) 23148458 | | Yes | Yes | No | Unclear
Salkeld (2013) no PMID | | Unclear | Unclear | No | Unclear
Wilkes (2013) 23835818 | | Yes | Yes | No | No
Watts (2013) 24274808 | | Yes | Yes | No | Yes
| High risk, but no cancer
| Breast—preventive treatment
Fagerlin (2011) 21442198 | 21 | Yes | Yes | Unclear | Unclear
Schwartz (2009) 19210013 | 17 | Yes^b^ | No | Unclear | Unclear
Ozanne (2007) 17319855 | | Unclear | Unclear | Unclear | No
van Roosmalen (2004) 15310772 | | Yes | Unclear | No | Unclear
| Breast—testing for genetic mutation
Lerman (1997) 8998184 | | Unclear | Unclear | No | Unclear
Green (2001) 11562929 | | Yes | Yes | No | No
Green (2004) 15280342 | | Unclear | Unclear | No | No
Miller (2005) 16377604 | | Unclear | Unclear | No | No
Albada (2012) 22394647 | | Yes | Yes | Unclear | Unclear
| Breast/Ovarian—testing for genetic mutation
Wakefield (2008) 17333332 | 13 | Unclear | Yes | Yes | No
Wakefield (2008) 18613319 | 13 | Unclear | Unclear | No | Yes
| Colorectal—testing for genetic mutation
Wakefield (2008) 18618513 | 13 | Unclear | Unclear | No | Yes
| Ovarian—preventive treatment
Tiller (2006) 16855125 | | Unclear | Unclear | Yes | No
| Early cancer
| Breast
Goel (2001) 11206942 | | Yes | Yes | No | No
Whelan (2004) 12697850 | 12 | Unclear | Unclear | Yes | Yes
Whelan (2003) 15280341 | 12 | Yes | Yes | No | No
Jibaja-Weiss (2011) 20609546 | 20 | Yes | Unclear | No | No
Street (1995) 8635032 | | Unclear | Unclear | Unclear | No
Vodermaier (2009) 19209172 | | Yes | Unclear | No | Unclear
Peele (2005) 15951457 | 22 | Unclear | Unclear | Unclear | Unclear
Lam (2013) 23835709 | | Yes | Yes | Yes | Unclear
Maslin (1998) no PMID | | Unclear | Unclear | Unclear | No
Cervical
McCaffery (2010) 20179125 | 15 | Yes | Unclear | Unclear | Unclear
| Colorectal
Manne (2010) 20142594 | | Unclear | Unclear | Unclear | Unclear
| Prostate
Berry (2013) 22153756 | 19 | Yes | Unclear | Unclear | Unclear
Davison (1997) 9190093 | | Unclear | Unclear | Unclear | No
Auvinen (2004) 14678367 | | Yes | Yes | No | No
Davison (2007) 17876177 | | Unclear | Yes | Unclear | Unclear
Mishel (2009) 19819096 | | Unclear | Unclear | Unclear | Unclear
Diefenbach (2012) 22246148 | | Unclear | Unclear | No | Unclear
Feldman-Stewart (2012) 22287534 | | Yes | Yes | Unclear | Unclear
Hacking (2013) 22570252 | | Yes | Yes | No | Unclear
van Tol-Geerdink (2013) 22882966 | | Unclear | Unclear | Unclear | No
Sawka (2012) 22753906 | | Yes | Yes | Unclear | No

a Based on information from Rubel 2010 PMID 20432110.

b Based on Hooker 2011 PMID 20876346.

## Key Question 2

See report text for comments on the risk of bias of studies in Key Question 2. Studies from Key Question 2 were not randomized controlled trials and the criteria in this table are not applicable.

Table G2 Information related to risk of bias in individual studies for Key Question 2

First Author, Year (PMID) | Population/body system and decision type Decision Aid ID^*^ | Low Risk of Bias due to Inadequate Randomized Sequence Generation | Low Risk of Bias due to Inadequate Allocation Concealment | Low Risk of Bias due to Inadequate Outcome Assessor Blinding | Low Risk of Bias due to Attrition (Attrition Rate below 20%)
| Screening
| Colorectal
Lin (2013)23381524 | | NA | NA | NA | NA
| Prostate
Gattellari (2005) 15824055 | | NA | NA | NA | NA
Feng (2013) 23835817 | | NA | NA | NA | NA
Bryan (2013) | Multiple | NA | NA | NA | NA
Uy (2013) | Multiple | NA | NA | NA | NA

* NA = Studies from Key Question 2 were not randomized controlled trials and the criteria in this table are not applicable.