# List of Excluded Studies

Reason | Citations
KQ1 - Not a DST | 1-138
KQ1 - Not an RCT | 139-206
KQ2 - No comparative aspect | 207-214
KQ2 - Not about promoting DST use | 215-285
Duplicate information | 15, 27, 286-297
Full text not in English | 298-310
Hypothetical choice/scenario | 311-316
No outcomes of interest | 291,317-319
< 10 in arm | 320
Wrong publication type (note: 2 abstracts in this section share a single citation) | 321-407
Wrong population | 408-426
Could not retrieve full text | 427-429

1 Schwartz MD, Valdimarsdottir HB, Peshkin BN, et al. Randomized noninferiority trial of telephone versus in-person genetic counseling for hereditary breast and ovarian cancer. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Mar. 1. 2014;32(7):618-26. [pmid: 24449235].
2 Abstracts presented at the 17th International Meeting of the European Society of Gynaecological Oncology. International Journal of Gynecological Cancer. 2011;21(12):S1. S1372. [doi: 10.097/IGC.0b013e318235bd21]. PMID:. [pmid: 21540665].
3 Oral Abstracts. Asia-Pacific Journal of Clinical Oncology. 2011;7:71-107. PMID:. [pmid: 22043534].
4 Abdullah F, O'Rorke M, Murray L, et al. Evaluation of a worksite cervical screening initiative to increase Pap smear uptake in Malaysia: a cluster randomized controlled trial. BioMed research international. 2013;2013:572126. [pmid: 24073411].
5 Abhyankar P, Bekker HL, Summers BA, et al. Why values elicitation techniques enable people to make informed decisions about cancer trial participation. Health expectations: an international journal of public participation in health care and health policy. Mar. Suppl 1. 2011;14:20-32. [pmid: 20629765].
6 Acera A, Rodriguez A, Trapero-Bertran M, et al. Economic evaluation of three populational screening strategies for cervical cancer in the county of Valles Occidental: CRICERVA clinical trial. BMC health services research. 2011;11:278. [pmid: 22011387].
7 Akl EA, Oxman AD, Herrin J, et al. Framing of health information messages. The Cochrane database of systematic reviews. 2011;(12). CD006777. [pmid: 22161408].
8 Albada A, van Dulmen S, Ausems MG, et al. A pre-visit website with question prompt sheet for counselees facilitates communication in the first consultation for breast cancer genetic counseling: findings from a randomized controlled trial. Genetics in medicine: official journal of the American College of Medical Genetics. May. 2012;14(5):535-42. [pmid: 22241101].
9 Allen JD, Othus MK, Hart A Jr., et al. Do men make informed decisions about prostate cancer screening? Baseline results from the “take the wheel” trial. Medical decision making: an international journal of the Society for Medical Decision Making. Jan-Feb. 2011;31(1):108-20. [pmid: 20484092].
10 Ambler N, Rumsey N, Harcourt D, et al. Specialist nurse counsellor interventions at the time of diagnosis of breast cancer: comparing ‘advocacy’ with a conventional approach. Journal of advanced nursing. Feb. 1999;29(2):445-53. [pmid: 10197945].
11 Aragones A, Schwartz MD, Shah NR, et al. A randomized controlled trial of a multilevel intervention to increase colorectal cancer screening among Latino immigrants in a primary care facility. Journal of general internal medicine. Jun. 2010;25(6):564-7. [pmid: 20213208].
12 Atkinson NL, Massett HA, Mylks C, et al. Assessing the impact of user-centered research on a clinical trial eHealth tool via counterbalanced research design. Journal of the American Medical Informatics Association: JAMIA. Jan-Feb. 2011;18(1):24-31. [pmid: 21169619].
13 Ballard JJ. Influence of a Fear Appeal on Colorectal Cancer Screening Among Insured Adults [PhD]. Ann Arbor. Walden University. 2012.
14 Bebis H, Reis N, Yavan T, et al. Effect of health education about cervical cancer and papanicolaou testing on the behavior, knowledge, and beliefs of Turkish women. International journal of gynecological cancer: official journal of the International Gynecological Cancer Society. Oct. 2012;22(8):1407-12. [pmid: 22932261].
15 Belkora J, Stupar L, O'Donnell S, et al. Decision support by telephone: randomized controlled trial in a rural community setting. Patient education and counseling. Oct. 2012;89(1):134-42. [pmid: 22776761].
16 Bernard E, Saint-Lary O, Haboubi L, et al. Cervical cancer screening: women's knowledge and participation. Sante Publique. May-Jun. 2013;25(3):255-62. [pmid: 24007901].
17 Blumenthal DS, Smith SA, Majett CD, et al. A trial of 3 interventions to promote colorectal cancer screening in African Americans. Cancer. Feb. 15. 2010;116(4):922-9. [pmid: 20052732].
18 Boguradzka A, Wiszniewski M, Kaminski MF, et al. The effect of primary care physician counseling on participation rate and use of sedation in colonoscopy-based colorectal cancer screening program--a randomized controlled study. Scandinavian journal of gastroenterology. Jul. 2014;49(7):878-84. [pmid: 24797871].
19 Boonzaier A, Schubach K, Troup K, et al. Development of a psychoeducational intervention for men with prostate cancer. Journal of psychosocial oncology. 2009;27(1):136-53. [pmid: 19197682].
20 Bowen DJ, Powers D. Effects of a mail and telephone intervention on breast health behaviors. Health education & behavior: the official publication of the Society for Public Health Education. Aug. 2010;37(4):479-89. [pmid: 20157016].
21 Bowen DJ, Robbins R, Bush N, et al. Effects of a Web-based intervention on women's breast health behaviors. Translational behavioral medicine. Mar. 2011;1(1):155-64. [pmid: 21643515].
22 Braithwaite D, Sutton S, Smithson WH, et al. Internet-based risk assessment and decision support for the management of familial cancer in primary care: a survey of GPs' attitudes and intentions. Family practice. Dec. 2002;19(6):587-90. [pmid: 12429659].
23 Broberg G, Jonasson JM, Ellis J, et al. Increasing participation in cervical cancer screening: telephone contact with long-term non-attendees in Sweden. Results from RACOMIP, a randomized controlled trial. International journal of cancer Journal international du cancer. Jul. 2013;133(1):164-71. [pmid: 23233356].
24 Brown RF, Butow PN, Boyle F, et al. Seeking informed consent to cancer clinical trials; evaluating the efficacy of doctor communication skills training. Psycho-oncology. Jun. 2007;16(6):507-16. [pmid: 16986176].
25 Carroll JC, Blaine S, Permaul J, et al. Efficacy of an educational intervention on family physicians' risk assessment and management of colorectal cancer. Journal of community genetics. 2014. Apr. 9. [pmid: 24715212].
26 Chhabra KR, Pollak KI, Lee SJ, et al. Physician communication styles in initial consultations for hematological cancer. Patient education and counseling. Dec. 2013;93(3):573-8. [pmid: 24035463].
27 Christy SM, Perkins SM, Tong Y, et al. Promoting colorectal cancer screening discussion: a randomized controlled trial. American journal of preventive medicine. Apr. 2013;44(4):325-9. [pmid: 23498096].
28 Clouston K, Katz A, Martens PJ, et al. Does access to a colorectal cancer screening website and/or a nurse-managed telephone help line provided to patients by their family physician increase fecal occult blood test uptake?: results from a pragmatic cluster randomized controlled trial. BMC cancer. 2014;14:263. [pmid: 24739235].
29 Daskalakis C, Vernon SW, Sifri R, et al. The effects of test preference, test access, and navigation on colorectal cancer screening. Cancer epidemiology, biomarkers & prevention: a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. Aug. 2014;23(8):1521-8. [pmid: 24813819].
30 de Bekker-Grob EW, Rose JM, Donkers B, et al. Men's preferences for prostate cancer screening: a discrete choice experiment. British journal of cancer. Feb. 19. 2013;108(3):533-41. [pmid: 23361056].
31 del Junco DJ, Vernon SW, Coan SP, et al. Promoting regular mammography screening I. A systematic assessment of validity in a randomized trial. Journal of the National Cancer Institute. Mar. 5. 2008;100(5):333-46. [pmid: 18314473].
32 Dillard AJ, Fagerlin A, Dal Cin S, et al. Narratives that address affective forecasting errors reduce perceived barriers to colorectal cancer screening. Soc Sci Med. Jul. 2010;71(1):45-52. [pmid: 20417005].
33 Duncan A, Zajac I, Flight I, et al. Comparison of mailed invitation strategies to improve fecal occult blood test participation in men: protocol for a randomized controlled trial. Trials. 2013;14:239. [pmid: 23902589].
34 Elliott TE, Elliott BA, Regal RR, et al. Lake Superior Rural Cancer Care Project, part II: provider knowledge. Cancer practice. Jan-Feb. 2001;9(1):37-46. [pmid: 11879271].
35 Ferron P. Impact of a Multifaceted Intervention on Promoting Adherence to Screening Colonoscopy among HIV/AIDS Population. 2011. PMID:.
36 Fiscella K, Yosha A, Hendren SK, et al. Get screened: a pragmatic randomized controlled trial to increase mammography and colorectal cancer screening in a large, safety net practice. BMC health services research. 2010;10:280. [pmid: 20863395].
37 Fisher CR, Wolfe CR, Reyna VF, et al. A signal detection analysis of gist-based discrimination of genetic breast cancer risk. Behavior research methods. Sep. 2013;45(3):613-22. [pmid: 23784010].
38 Flight IH, Wilson CJ, Zajac IT, et al. Decision Support and the Effectiveness of Web-based Delivery and Information Tailoring for Bowel Cancer Screening: An Exploratory Study. JMIR research protocols. 2012;1(2):e12. [pmid: 23611950].
39 Gimeno-Garcia AZ, Quintero E, Nicolas-Perez D, et al. Impact of an educational video-based strategy on the behavior process associated with colorectal cancer screening: a randomized controlled study. Cancer epidemiology. Oct. 2009;33(3-4):216-22. [pmid: 19747893].
40 Ginsburg OM, Chowdhury M, Wu W, et al. An mHealth model to increase clinic attendance for breast symptoms in rural Bangladesh: can bridging the digital divide help close the cancer divide?. The oncologist. Feb. 2014;19(2):177-85. [pmid: 24396050].
41 Giordano L, Stefanini V, Senore C, et al. The impact of different communication and organizational strategies on mammography screening uptake in women aged 40-45 years. European journal of public health. Jun. 2012;22(3):413-8. [pmid: 21746751].
42 Giorgi Rossi P, Marsili LM, Camilloni L, et al. The effect of self-sampled HPV testing on participation to cervical cancer screening in Italy: a randomised controlled trial (ISRCTN96071600). British journal of cancer. Jan. 18. 2011;104(2):248-54. [pmid: 21179038].
43 Goss C, Ghilardi A, Deledda G, et al. INvolvement of breast CAncer patients during oncological consultations: a multicentre randomised controlled trial--the INCA study protocol. BMJ open. 2013;3(5). [pmid: 23645911].
44 Graves KD, Wenzel L, Schwartz MD, et al. Randomized controlled trial of a psychosocial telephone counseling intervention in BRCA1 and BRCA2 mutation carriers. Cancer epidemiology, biomarkers & prevention: a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. Mar. 2010;19(3):648-54. [pmid: 20200423].
45 Green BB, Wang CY, Anderson ML, et al. An automated intervention with stepped increases in support to increase uptake of colorectal cancer screening: a randomized trial. Annals of internal medicine. Mar. 5. 2013;158(5 Pt 1):301-11. [pmid: 23460053].
46 Gustafson DH, Hawkins R, McTavish F, et al. Internet-Based Interactive Support for Cancer Patients: Are Integrated Systems Better?. The Journal of communication. Jun. 2008;58(2):238-57. [pmid: 21804645].
47 Haakenson CP, Vickers KS, Cha SS, et al. Efficacy of a simple, low-cost educational intervention in improving knowledge about risks and benefits of screening mammography. Mayo Clinic proceedings. Jun. 2006;81(6):783-91. [pmid: 16770979].
48 Hack TF, Pickles T, Ruether JD, et al. Predictors of distress and quality of life in patients undergoing cancer therapy: impact of treatment type and decisional role. Psycho-oncology. Jun. 2010;19(6):606-16. [pmid: 19557823].
49 Hajian S, Vakilian K, Najabadi KM, et al. Effects of education based on the health belief model on screening behavior in high risk women for breast cancer, Tehran, Iran. Asian Pacific journal of cancer prevention: APJCP. 2011;12(1):49-54. [pmid: 21517230].
50 Hegenscheid K, Hoffmann W, Fochler S, et al. Telephone counseling and attendance in a national mammography-screening program a randomized controlled trial. American journal of preventive medicine. Oct. 2011;41(4):421-7. [pmid: 21961470].
51 Heyn L, Ruland CM, Finset A. Effects of an interactive tailored patient assessment tool on eliciting and responding to cancer patients' cues and concerns in clinical consultations with physicians and nurses. Patient education and counseling. Feb. 2012;86(2):158-65. [pmid: 21592719].
52 Hoffner B, Bauer-Wu S, Hitchcock-Bryan S, et al. “Entering a Clinical Trial: Is it Right for You?”: a randomized study of The Clinical Trials Video and its impact on the informed consent process. Cancer. Apr. 1. 2012;118(7):1877-83. [pmid: 22009665].
53 Hol L, van Leerdam ME, van Ballegooijen M, et al. Screening for colorectal cancer: randomised trial comparing guaiac-based and immunochemical faecal occult blood testing and flexible sigmoidoscopy. Gut. Jan. 2010;59(1):62-8. [pmid: 19671542].
54 Hopfer S. Culture-centric Narratives as Health Message Design Strategy: Developing an HPV Vaccine Intervention for College-aged Women. Pennsylvania State University. 2009.
55 Huber J, Ihrig A, Yass M, et al. UP-02.156 Improving the Preoperative Consultation Before Radical Prostatectomy Using Multimedia Support: A Randomized Controlled Trial. Urology. 2011;78(3):S314. PMID:.
56 Huyghe E, Martinetti P, Sui D, et al. Banking on Fatherhood: pilot studies of a computerized educational tool on sperm banking before cancer treatment. Psycho-oncology. Sep. 2009;18(9):1011-4. [pmid: 19061198].
57 Hwang KO, Ottenbacher AJ, Graham AL, et al. Online narratives and peer support for colorectal cancer screening: a pilot randomized trial. American journal of preventive medicine. Jul. 2013;45(1):98-107. [pmid: 23790994].
58 Ihrig A, Herzog W, Huber CG, et al. Multimedia support in preoperative patient education for radical prostatectomy: the physicians' point of view. Patient education and counseling. May. 2012;87(2):239-42. [pmid: 21945598].
59 Janda M, Youl PH, Lowe JB, et al. What motivates men age > or =50 years to participate in a screening program for melanoma?. Cancer. Aug. 15. 2006;107(4):815-23. [pmid: 16832794].
60 Jandorf L, Bursac Z, Pulley L, et al. Breast and cervical cancer screening among Latinas attending culturally specific educational programs. Progress in community health partnerships: research, education, and action. Fall. 2008;2(3):195-204. [pmid: 20208198].
61 Jensen H, Svanholm H, Stovring H, et al. A primary healthcare-based intervention to improve a Danish cervical cancer screening programme: a cluster randomised controlled trial. Journal of epidemiology and community health. Jul. 2009;63(7):510-5. [pmid: 19228681].
62 Jerant A, Kravitz RL, Sohler N, et al. Sociopsychological tailoring to address colorectal cancer screening disparities: a randomized controlled trial. Annals of family medicine. May-Jun. 2014;12(3):204-14. [pmid: 24821891].
63 Jones JK, Kamani SA, Bush PJ, et al. Development and evaluation of an educational interactive CD-ROM for teens with cancer. Pediatric blood & cancer. Sep. 2010;55(3):512-9. [pmid: 20533523].
64 Katz ML, Fisher JL, Fleming K, et al. Patient activation increases colorectal cancer screening rates: a randomized trial among low-income minority patients. Cancer epidemiology, biomarkers & prevention: a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. Jan. 2012;21(1):45-52. [pmid: 22068288].
65 Kirkegaard P, Vedsted P, Edwards A, et al. A cluster-randomised, parallel group, controlled intervention study of genetic prostate cancer risk assessment and use of PSA tests in general practice--the ProCaRis study: study protocol. BMJ open. 2013;3(3). [pmid: 23457331].
66 Koretz RL. ACP Journal Club. Invitation to screening with colonoscopy had lower participation but similar yield as CT colonography. Annals of internal medicine. Jul. 17. 2012;157(2):JC2-5. [pmid: 22801697].
67 Krist AH, Woolf SH, Johnson RE, et al. Patient education on prostate cancer screening and involvement in decision making. Annals of family medicine. Mar-Apr. 2007;5(2):112-9. [pmid: 17389534].
68 Krist AH, Woolf SH, Rothemich SF, et al. Interactive preventive health record to enhance delivery of recommended care: a randomized trial. Annals of family medicine. Jul-Aug. 2012;10(4):312-9. [pmid: 22778119].
69 Kumar EE. The Effects of Culturally Sensitive Education in Driving South Asian Indian Immigrant Women Towards Mammography Screening in New Jersey. 2011. PMID:.
70 Kutner JS, Foehner K, Steiner JF. Evaluation of the impact of a pre-visit questionnaire for addressing cancer patients' information needs. Journal of Cancer Education. 1999;14(4):248-53. PMID:.
71 Landrey AR, Matlock DD, Andrews L, et al. Shared decision making in prostate-specific antigen testing: the effect of a mailed patient flyer prior to an annual exam. Journal of primary care & community health. Jan. 2013;4(1):67-74. [pmid: 23799692].
72 Larkey LK, Herman PM, Roe DJ, et al. A cancer screening intervention for underserved Latina women by lay educators. J Womens Health (Larchmt). May. 2012;21(5):557-66. [pmid: 22416791].
73 Lau DT, Machizawa S, Demonte W, et al. Colorectal cancer knowledge, attitudes, screening, and intergenerational communication among Japanese American families: an exploratory, community-based participatory study. Journal of cross-cultural gerontology. Mar. 2013;28(1):89-101. [pmid: 23263883].
74 Leader A, Daskalakis C, Braddock CH 3rd, et al. Measuring informed decision making about prostate cancer screening in primary care. Medical decision making: an international journal of the Society for Medical Decision Making. Mar-Apr. 2012;32(2):327-36. [pmid: 21685377].
75 Lee MH, Lee YY, Jung da W, et al. Effectiveness of interventions to increase the participation rate of gastric cancer screening in the Republic of Korea: a pilot study. Asian Pacific journal of cancer prevention: APJCP. 2012;13(3):861-6. [pmid: 22631662].
76 Lewis CL, Pignone MP, Sheridan SL, et al. A randomized trial of three videos that differ in the framing of information about mammography in women 40 to 49 years old. Journal of general internal medicine. Nov. 2003;18(11):875-83. [pmid: 14687272].
77 Lin ZC, Effken JA. Effects of a tailored web-based educational intervention on women's perceptions of and intentions to obtain mammography. Journal of clinical nursing. May. 2010;19(9-10):1261-9. [pmid: 20345827].
78 Linder SK, Kallen MA, Mullen PD, et al. Physician behaviors to promote informed decisions for prostate cancer screening: a National Research Network study. Journal of cancer education: the official journal of the American Association for Cancer Education. Jun. 2014;29(2):345-9. [pmid: 24488590].
79 Lisi D, Hassan C, Crespi M. Participation in colorectal cancer screening with FOBT and colonoscopy: an Italian, multicentre, randomized population study. Digestive and liver disease: official journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. May. 2010;42(5):371-6. [pmid: 19747888].
80 Lo SS, Mumby PB, Norton J, et al. Prospective multicenter study of the impact of the 21-gene recurrence score assay on medical oncologist and patient adjuvant breast cancer treatment selection. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Apr. 1. 2010;28(10):1671-6. [pmid: 20065191].
81 Love GD, Mouttapa M, Tanjasiri SP. Everybody's talking: using entertainment-education video to reduce barriers to discussion of cervical cancer screening among Thai women. Health education research. Oct. 2009;24(5):829-38. [pmid: 19332440].
82 Luszczynska A, Goc G, Scholz U, et al. Enhancing intentions to attend cervical cancer screening with a stage-matched intervention. British journal of health psychology. Feb. 2011;16(Pt 1):33-46. [pmid: 21226782].
83 Makoul G, Cameron KA, Baker DW, et al. A multimedia patient education program on colorectal cancer screening increases knowledge and willingness to consider screening among Hispanic/Latino patients. Patient education and counseling. Aug. 2009;76(2):220-6. [pmid: 19250791].
84 Manne SL, Coups EJ, Markowitz A, et al. A randomized trial of generic versus tailored interventions to increase colorectal cancer screening among intermediate risk siblings. Annals of behavioral medicine: a publication of the Society of Behavioral Medicine. Apr. 2009;37(2):207-17. [pmid: 19418107].
85 Martinez LS, Schwartz JS, Freres D, et al. Patient-clinician information engagement increases treatment decision satisfaction among cancer patients through feeling of being informed. Patient education and counseling. Dec. 2009;77(3):384-90. [pmid: 19815365].
86 Miller SM, Roussi P, Scarpato J, et al. Randomized trial of print messaging: the role of the partner and monitoring style in promoting provider discussions about prostate cancer screening among African American men. Psycho-oncology. Apr. 2014;23(4):404-11. [pmid: 24130097].
87 Mishra SI, Luce PH, Baquet CR. Increasing pap smear utilization among Samoan women: results from a community based participatory randomized trial. Journal of health care for the poor and underserved. May. 2009;20(2 Suppl):85-101. [pmid: 19711495].
88 Morgan PD, Fogel J, Tyler ID, et al. Culturally targeted educational intervention to increase colorectal health awareness among African Americans. Journal of health care for the poor and underserved. Aug. 2010;21(3 Suppl):132-47. [pmid: 20675951].
89 Myers RE, Bittner-Fagan H, Daskalakis C, et al. A randomized controlled trial of a tailored navigation and a standard intervention in colorectal cancer screening. Cancer epidemiology, biomarkers & prevention: a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. Jan. 2013;22(1):109-17. [pmid: 23118143].
90 Myers RE, Manne SL, Wilfond B, et al. A randomized trial of genetic and environmental risk assessment (GERA) for colorectal cancer risk in primary care: trial design and baseline findings. Contemporary clinical trials. Jan. 2011;32(1):25-31. [pmid: 20828635].
91 Nuno T, Martinez ME, Harris R, et al. A Promotora-administered group education intervention to promote breast and cervical cancer screening in a rural community along the U.S.-Mexico border: a randomized controlled trial. Cancer causes & control: CCC. Mar. 2011;22(3):367-74. [pmid: 21184267].
92 O'Brien MA, Ellis PM, Whelan TJ, et al. Physician-related facilitators and barriers to patient involvement in treatment decision making in early stage breast cancer: perspectives of physicians and patients. Health expectations: an international journal of public participation in health care and health policy. Dec. 2013;16(4):373-84. [pmid: 21923813].
93 O'Donnell S, Goldstein B, Dimatteo MR, et al. Adherence to mammography and colorectal cancer screening in women 50-80 years of age the role of psychological distress. Women's health issues: official publication of the Jacobs Institute of Women's Health. Sep. 2010;20(5):343-9. [pmid: 20800770].
94 Oeffinger KC, Hudson MM, Mertens AC, et al. Increasing rates of breast cancer and cardiac surveillance among high-risk survivors of childhood Hodgkin lymphoma following a mailed, one-page survivorship care plan. Pediatric blood & cancer. May. 2011;56(5):818-24. [pmid: 21370417].
95 Orringer JS, Fendrick AM, Trask PC, et al. The effects of a professionally produced videotape on education and anxiety/distress levels for patients with newly diagnosed melanoma: a randomized, prospective clinical trial. Journal of the American Academy of Dermatology. Aug. 2005;53(2):224-9. [pmid: 16021114].
96 Parish SL, Rose RA, Luken K, et al. Cancer Screening Knowledge Changes Results From a Randomized Control Trial of Women With Developmental Disabilities. Research on Social Work Practice. 2012;22(1):43-53. PMID:.
97 Parsa P, Kandiah M. Efficacy of an educational intervention on breast cancer screening behaviour among malaysian women. International Journal of Gynecological Cancer. 2011;21(12):S965. PMID:.
98 Peterson JJ, Suzuki R, Walsh ES, et al. Improving cancer screening among women with mobility impairments: randomized controlled trial of a participatory workshop intervention. American journal of health promotion: AJHP. Mar-Apr. 2012;26(4):212-6. [pmid: 22375570].
99 Phillips CE, Rothstein JD, Beaver K, et al. Patient navigation to increase mammography screening among inner city women. Journal of general internal medicine. Feb. 2011;26(2):123-9. [pmid: 20931294].
100 Pignone M, Winquist A, Schild LA, et al. Effectiveness of a patient and practice-level colorectal cancer screening intervention in health plan members: the CHOICE trial. Cancer. Aug. 1. 2011;117(15):3352-62. [pmid: 21319147].
101 Pignone MP, Brenner AT, Hawley S, et al. Conjoint analysis versus rating and ranking for values elicitation and clarification in colorectal cancer screening. Journal of general internal medicine. Jan. 2012;27(1):45-50. [pmid: 21870192].
102 Pignone MP, Howard K, Brenner AT, et al. Comparing 3 techniques for eliciting patient values for decision making about prostate-specific antigen screening: a randomized controlled trial. JAMA internal medicine. Mar. 11. 2013;173(5):362-8. [pmid: 23400279].
103 Rawl SM, Champion VL, Scott LL, et al. A randomized trial of two print interventions to increase colon cancer screening among first-degree relatives. Patient education and counseling. May. 2008;71(2):215-27. [pmid: 18308500].
104 Robinson JK, Gaber R, Hultgren B, et al. Skin self-examination education for early detection of melanoma: a randomized controlled trial of Internet, workbook, and in-person interventions. Journal of medical Internet research. 2014;16(1):e7. [pmid: 24418949].
105 Rosenzweig M, Brufsky A, Rastogi P, et al. The attitudes, communication, treatment, and support intervention to reduce breast cancer treatment disparity. Oncology nursing forum. Jan. 2011;38(1):85-9. [pmid: 21186164].
106 Rubinstein WS, Acheson LS, O'Neill SM, et al. Clinical utility of family history for cancer screening and referral in primary care: a report from the Family Healthware Impact Trial. Genetics in medicine: official journal of the American College of Medical Genetics. Nov. 2011;13(11):956-65. [pmid: 22075527].
107 Ruland CM, Holte HH, Roislien J, et al. Effects of a computer-supported interactive tailored patient assessment tool on patient care, symptom distress, and patients' need for symptom management support: a randomized clinical trial. Journal of the American Medical Informatics Association: JAMIA. Jul-Aug. 2010;17(4):403-10. [pmid: 20595307].
108 Ryhanen AM, Rankinen S, Siekkinen M, et al. The impact of an empowering Internet-based Breast Cancer Patient Pathway programme on breast cancer patients' knowledge: a randomised control trial. Patient education and counseling. Aug. 2012;88(2):224-31. [pmid: 22425373].
109 Sadler GR, Ko CM, Wu P, et al. A cluster randomized controlled trial to increase breast cancer screening among African American women: the black cosmetologists promoting health program. Journal of the National Medical Association. Aug. 2011;103(8):735-45. [pmid: 22046851].
110 Schapira MM, VanRuiswyk J. The effect of an illustrated pamphlet decision-aid on the use of prostate cancer screening tests. The Journal of family practice. May. 2000;49(5):418-24. [pmid: 10836772].
111 Schroy PC 3rd, Mylvaganam S, Davidson P. Provider perspectives on the utility of a colorectal cancer screening decision aid for facilitating shared decision making. Health expectations: an international journal of public participation in health care and health policy. Feb. 2014;17(1):27-35. [pmid: 21902773].
112 Sifri R, Rosenthal M, Hyslop T, et al. Factors associated with colorectal cancer screening decision stage. Preventive medicine. Sep-Oct. 2010;51(3-4):329-31. [pmid: 20600255].
113 Simon SR, Zhang F, Soumerai SB, et al. Failure of automated telephone outreach with speech recognition to improve colorectal cancer screening: a randomized controlled trial. Archives of internal medicine. Feb. 8. 2010;170(3):264-70. [pmid: 20142572].
114 Smith A, Juraskova I, Butow P, et al. Sharing vs. caring--the relative impact of sharing decisions versus managing emotions on patient outcomes. Patient education and counseling. Feb. 2011;82(2):233-9. [pmid: 20434865].
115 Smith JL, Wilson KM, Orians CE, et al. AMIGAS: building a cervical cancer screening intervention for public health practice. J Womens Health (Larchmt). Sep. 2013;22(9):718-23. [pmid: 23930983].
116 Smith S. Using decision aids for informed choice in bowel cancer screening. Asia Pac J Clin Oncol. 2011;7:88-9. PMID:.
117 Snijders HS, Kunneman M, Bonsing BA, et al. Preoperative risk information and patient involvement in surgical treatment for rectal and sigmoid cancer. Colorectal disease: the official journal of the Association of Coloproctology of Great Britain and Ireland. Feb. 2014;16(2):O43-9. [pmid: 24188458].
118 Steckelberg A, Albrecht M, Kezle A, et al. Impact of numerical information on risk knowledge regarding human papillomavirus (HPV) vaccination among schoolgirls: a randomised controlled trial. German medical science: GMS e-journal. 2013;11:Doc15. [pmid: 24198750].
119 Steckelberg A, Hulfenhaus C, Haastert B, et al. Effect of evidence based risk information on “informed choice” in colorectal cancer screening: randomised controlled trial. BMJ. 2011;342:d3193. [pmid: 21636633].
120 Stephens JH, Moore JW. Can targeted intervention in CRC patients' relatives influence screening behaviour? A pilot study. Colorectal disease: the official journal of the Association of Coloproctology of Great Britain and Ireland. Feb. 2008;10(2):179-86. [pmid: 17459064].
121 Stoop EM, de Haan MC, de Wijkerslooth TR, et al. Participation and yield of colonoscopy versus non-cathartic CT colonography in population-based screening for colorectal cancer: a randomised controlled trial. The lancet oncology. Jan. 2012;13(1):55-64. [pmid: 22088831].
122 Stoop EM, de Wijkerslooth TR, Bossuyt PM, et al. Face-to-face vs telephone pre-colonoscopy consultation in colorectal cancer screening; a randomised trial. British journal of cancer. Sep. 25. 2012;107(7):1051-8. [pmid: 22918392].
123 Taylor V, Thompson B, Lessler D, et al. A clinic-based mammography intervention targeting inner-city women. Journal of general internal medicine. Feb. 1999;14(2):104-11. [pmid: 10051781].
124 Thompson VL, Kalesan B, Wells A, et al. Comparing the use of evidence and culture in targeted colorectal cancer communication for African Americans. Patient education and counseling. Dec. Suppl. 2010;81:S22-33. [pmid: 20702056].
125 Tinmouth JM, Patel J, Austin PC, et al. 216 Increasing Participation in Colorectal Cancer Screening: Results From a Randomized Trial of Directly Mailed FOBT Kits in a Hard to Reach Population. Gastroenterology. 2013;144(5):S-46. PMID:.
126 Van Roosbroeck S, Hoeck S, Van Hal G. Population-based screening for colorectal cancer using an immunochemical faecal occult blood test: a comparison of two invitation strategies. Cancer epidemiology. Oct. 2012;36(5):e317-24. [pmid: 22560885].
127 van Roosmalen MS, Stalmeier PF, Verhoef LC, et al. Randomised trial of a decision aid and its timing for women being tested for a BRCA1/2 mutation. British journal of cancer. Jan. 26. 2004;90(2):333-42. [pmid: 14735173].
128 van Vugt HA, Roobol MJ, Busstra M, et al. Compliance with biopsy recommendations of a prostate cancer risk calculator. BJU international. May. 2012;109(10):1480-8. [pmid: 21933335].
129 van Vugt HA, Roobol MJ, van der Poel HG, et al. Selecting men diagnosed with prostate cancer for active surveillance using a risk calculator: a prospective impact study. BJU international. Jul. 2012;110(2):180-7. [pmid: 22112199].
130 Wahab S, Menon U, Szalacha L. Motivational interviewing and colorectal cancer screening: a peek from the inside out. Patient education and counseling. Aug. 2008;72(2):210-7. [pmid: 18467066].
131 Weinberg DS, Keenan E, Ruth K, et al. A randomized comparison of print and web communication on colorectal cancer screening. JAMA internal medicine. Jan. 28. 2013;173(2):122-9. [pmid: 23128366].
132 Wells KJ, McIntyre J, Gonzalez LE, et al. Feasibility trial of a Spanish-language multimedia educational intervention. Clin Trials. Oct. 2013;10(5):767-74. [pmid: 23935161].
133 Wevers MR, Aaronson NK, Verhoef S, et al. Impact of rapid genetic counselling and testing on the decision to undergo immediate or delayed prophylactic mastectomy in newly diagnosed breast cancer patients: findings from a randomised controlled trial. British journal of cancer. Feb. 18. 2014;110(4):1081-7. [pmid: 24423928].
134 Wiszniewski M, Boguradzka A, Kaminski MF, et al. Tu1187 Magnitude of the Effect of Physician Counseling on the Participation Rate and Utilization of Sedation in a Colonoscopy-Based Colorectal Cancer-Screening Program-Randomized Controlled Study. Gastroenterology. 2012;142(5):S-769. PMID:.
135 Wolf AM, Nasser JF, Schorling JB. The impact of informed consent on patient interest in prostate-specific antigen screening. Archives of internal medicine. Jun. 24. 1996;156(12):1333-6. [pmid: 8651843].
136 Wolf AM, Schorling JB. Preferences of elderly men for prostate-specific antigen screening and the impact of informed consent. The journals of gerontology Series A, Biological sciences and medical sciences. May. 1998;53(3):M195-200. [pmid: 9597051].
137 Wolf AM, Schorling JB. Does informed consent alter elderly patients' preferences for colorectal cancer screening? Results of a randomized trial. Journal of general internal medicine. Jan. 2000;15(1):24-30. [pmid: 10632830].
138 Wong AD, Kirby J, Guyatt GH, et al. Randomized controlled trial comparing telephone and mail follow-up for recruitment of participants into a clinical trial of colorectal cancer screening. Trials. 2013;14:40. [pmid: 23399518].
139 PCa screening guideline: informed decision is crucial. Urology Times. 2010;38(4):8. PMID:.
140 Au AH, Lam WW, Chan MC, et al. Development and pilot-testing of a Decision Aid for use among Chinese women facing breast cancer surgery. Health expectations: an international journal of public participation in health care and health policy. Dec. 2011;14(4):405-16. [pmid: 21223468].
141 Avery KN, Blazeby JM, Lane JA, et al. Decision-making about PSA testing and prostate biopsies: a qualitative study embedded in a primary care randomised trial. European urology. Jun. 2008;53(6):1186-93. [pmid: 17709169].
142 Brown RF, Butow PN, Juraskova I, et al. Sharing decisions in breast cancer care: Development of the Decision Analysis System for Oncology (DAS-O) to identify shared decision making during treatment consultations. Health expectations: an international journal of public participation in health care and health policy. Mar. 2011;14(1):29-37. [pmid: 20629766].
143 Butow P, Devine R, Boyer M, et al. Cancer consultation preparation package: changing patients but not physicians is not enough. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Nov. 1. 2004;22(21):4401-9. [pmid: 15514382].
144 Carey M, Sanson-Fisher R, Macrae F, et al. Improving adherence to surveillance and screening recommendations for people with colorectal cancer and their first degree relatives: a randomized controlled trial. BMC cancer. 2012;12:62. [pmid: 22314015].
145 Clouston K, Katz A, Martens PJ, et al. Does access to a colorectal cancer screening website and/or a nurse-managed telephone help line provided to patients by their family physician increase fecal occult blood test uptake?: A pragmatic cluster randomized controlled trial study protocol. BMC cancer. 2012;12:182. [pmid: 22607726].
146 Cornuz J, Junod N, Pasche O, et al. Cancer screening in clinical practice: the value of shared decision-making. Revue medicale suisse. Jul. 14. 2010;6(256):1410-4. [pmid: 20701018].
147 Costanza ME, Luckmann R, White MJ, et al. Design and methods for a randomized clinical trial comparing three outreach efforts to improve screening mammography adherence. BMC health services research. 2011;11:145. [pmid: 21639900].
148 Costanza ME, Luckmann RS, Rosal M, et al. Helping men make an informed decision about prostate cancer screening: a pilot study of telephone counseling. Patient education and counseling. Feb. 2011;82(2):193-200. [pmid: 20554423].
149 Damery S, Smith S, Clements A, et al. Evaluating the effectiveness of GP endorsement on increasing participation in the NHS Bowel Cancer Screening Programme in England: study protocol for a randomized controlled trial. Trials. 2012;13:18. [pmid: 22348399].
150 Davis L, Villamin C, Blackburn R, et al. Individualized Care Planning Process. Biology of Blood and Marrow Transplant. 19(2):S358-S9. PMID:.
151 Davison BJ, Degner LF. Feasibility of using a computer-assisted intervention to enhance the way women with breast cancer communicate with their physicians. Cancer nursing. Dec. 2002;25(6):417-24. [pmid: 12464832].
152 de Haan MC, de Wijkerslooth TR, Stoop E, et al. Informed decision-making in colorectal cancer screening using colonoscopy or CT-colonography. Patient education and counseling. Jun. 2013;91(3):318-25. [pmid: 23399437].
153 Denters MJ, Deutekom M, Fockens P, et al. Implementation of population screening for colorectal cancer by repeated fecal occult blood test in the Netherlands. BMC gastroenterology. 2009;9:28. [pmid: 19393087].
154 Doerr M, Edelman E, Gabitzsch E, Eng C, Teng K. Formative evaluation of clinician experience with integrating family history-based clinical decision support into clinical practice. Journal of Personalized Medicine. 2014;4(2):115-36. PMID:. [pmid: 25563219].
155 Dolan JG, Boohaker E, Allison J, et al. Can Streamlined Multicriteria Decision Analysis Be Used to Implement Shared Decision Making for Colorectal Cancer Screening?. Medical decision making: an international journal of the Society for Medical Decision Making. Dec. 3. 2013;34(6):746-55. [pmid: 24300851].
156 Domenighetti G, Grilli R, Maggi JR. Does provision of an evidence-based information change public willingness to accept screening tests?. Health expectations: an international journal of public participation in health care and health policy. Jun. 2000;3(2):145-50. [pmid: 11281921].
157 Donovan JL. Presenting treatment options to men with clinically localized prostate cancer: the acceptability of active surveillance/monitoring. Journal of the National Cancer Institute Monographs. Dec. 2012;2012(45):191-6. [pmid: 23271772].
158 Dorfman CS, Williams RM, Kassan EC, et al. The development of a web- and a print-based decision aid for prostate cancer screening. BMC medical informatics and decision making. 2010;10:12. [pmid: 20199680].
159 Driscoll DL, Rupert DJ, Golin CE, et al. Promoting prostate-specific antigen informed decision-making. Evaluating two community-level interventions. American journal of preventive medicine. Aug. 2008;35(2):87-94. [pmid: 18617077].
160 Duncan LR, Latimer AE, Pomery E, et al. Testing messages to encourage discussion of clinical trials among cancer survivors and their physicians: examining monitoring style and message detail. Journal of cancer education: the official journal of the American Association for Cancer Education. Mar. 2013;28(1):119-26. [pmid: 23143846].
161 Ellison GL, Weinrich SP, Lou M, et al. A randomized trial comparing web-based decision aids on prostate cancer knowledge for African-American men. Journal of the National Medical Association. Oct. 2008;100(10):1139-45. [pmid: 18942274].
162 Elwyn G, Lloyd A, Joseph-Williams N, et al. Option Grids: shared decision making made easier. Patient education and counseling. Feb. 2013;90(2):207-12. [pmid: 22854227].
163 Engelen V, van Zwieten M, Koopman H, et al. The influence of patient reported outcomes on the discussion of psychosocial issues in children with cancer. Pediatric blood & cancer. Jul. 15. 2012;59(1):161-6. [pmid: 22271750].
164 Engelman KK, Cupertino AP, Daley CM, et al. Engaging diverse underserved communities to bridge the mammography divide. BMC public health. 2011;11:47. [pmid: 21255424].
165 Feldman-Stewart D, Brundage MD, Van Manen L, et al. Patient-focussed decision-making in early-stage prostate cancer: insights from a cognitively based decision aid. Health expectations: an international journal of public participation in health care and health policy. Jun. 2004;7(2):126-41. [pmid: 15117387].
166 Garvelink MM, ter Kuile MM, Fischer MJ, et al. Development of a Decision Aid about fertility preservation for women with breast cancer in The Netherlands. Journal of psychosomatic obstetrics and gynaecology. Dec. 2013;34(4):170-8. [pmid: 24188788].
167 Green BB, Wang CY, Horner K, et al. Systems of support to increase colorectal cancer screening and follow-up rates (SOS): design, challenges, and baseline characteristics of trial participants. Contemporary clinical trials. Nov. 2010;31(6):589-603. [pmid: 20674774].
168 Greenspoon JN, Whitton A, Whelan T, et al. Robotic radiosurgery for the treatment of 1-3 brain metastases: a pragmatic application of cost-benefit analysis using willingness-to-pay. Technology in cancer research & treatment. Dec. 2013;12(6):517-23. [pmid: 23745785].
169 Hacking B, Scott SE, Wallace LM, et al. Navigating healthcare: a qualitative study exploring prostate cancer patients' and doctors' experience of consultations using a decision-support intervention. Psycho-oncology. Jun. 2014;23(6):665-71. [pmid: 24677394].
170 Hoffman RM. Clinical practice. Screening for prostate cancer. The New England journal of medicine. Nov. 24. 2011;365(21):2013-9. [pmid: 22029754].
171 James AS, Richardson V, Wang JS, et al. Systems intervention to promote colon cancer screening in safety net settings: protocol for a community-based participatory randomized controlled trial. Implementation science: IS. 2013;8:58. [pmid: 23731594].
172 Jibaja-Weiss ML, Volk RJ, Granch TS, et al. Entertainment education for informed breast cancer treatment decisions in low-literate women: development and initial evaluation of a patient decision aid. Journal of cancer education: the official journal of the American Association for Cancer Education. Fall. 2006;21(3):133-9. [pmid: 17371175].
173 Joseph-Williams N, Evans R, Edwards A, et al. Supporting informed decision making online in 20 minutes: an observational web-log study of a PSA test decision aid. Journal of medical Internet research. 2010;12(2):e15. [pmid: 20507844].
174 Juraskova I, Butow P, Lopez A, et al. Improving informed consent: pilot of a decision aid for women invited to participate in a breast cancer prevention trial (IBIS-II DCIS). Health expectations: an international journal of public participation in health care and health policy. Sep. 2008;11(3):252-62. [pmid: 18816321].
175 Kaplan AL, Crespi CM, Saucedo JD, et al. Decisional conflict in economically disadvantaged men with newly diagnosed prostate cancer: Baseline results from a shared decision-making trial. Cancer. Sep. 1. 2014;120(17):2721-7. [pmid: 24816472].
176 Katz ML, Broder-Oldach B, Fisher JL, et al. Patient-provider discussions about colorectal cancer screening: who initiates elements of informed decision making?. Journal of general internal medicine. Sep. 2012;27(9):1135-41. [pmid: 22476985].
177 Kim SI, Kang JY, Lee HW, et al. A survey conducted on patients' and urologists' perceptions of benign prostatic hyperplasia. Urologia internationalis. 2011;86(3):278-83. [pmid: 21273763].
178 Kinsella J, Acher P, Ashfield A, et al. Demonstration of erectile management techniques to men scheduled for radical prostatectomy reduces long-term regret: a comparative cohort study. BJU international. Jan. 2012;109(2):254-8. [pmid: 21883815].
179 Ko LK, Reuland D, Jolles M, et al. Cultural and linguistic adaptation of a multimedia colorectal cancer screening decision aid for Spanish-speaking Latinos. Journal of health communication. 2014;19(2):192-209. [pmid: 24328496].
180 L R. A patchwork of life: A bilingual breast cancer treatment patient decision aid targeted at medically underserved women. Cancer Epidemiology Biomarkers & Prevention. 2011;20(10 (suppl.)). PMID:.
181 Lairson DR, Dicarlo M, Deshmuk AA, et al. Cost-effectiveness of a standard intervention versus a navigated intervention on colorectal cancer screening use in primary care. Cancer. Apr. 1. 2014;120(7):1042-9. [pmid: 24435411].
182 Lam WW, Kwok M, Chan M, et al. Does the use of shared decision-making consultation behaviors increase treatment decision-making satisfaction among Chinese women facing decision for breast cancer surgery?. Patient education and counseling. Feb. 2014;94(2):243-9. [pmid: 24316055].
183 Legare F, Ratte S, Stacey D, et al. Interventions for improving the adoption of shared decision making by healthcare professionals. The Cochrane database of systematic reviews. 2010;(5). CD006732. [pmid: 20464744].
184 Lewis CL, Brenner AT, Griffith JM, et al. Two controlled trials to determine the effectiveness of a mailed intervention to increase colon cancer screening. North Carolina medical journal. Mar-Apr. 2012;73(2):93-8. [pmid: 22860316].
185 Linder SK. Affect and cognition measures in preference-based decisions: Validity testing of the Ottawa Decisional Conflict Scale and a decision-specific anxiety measure with men eligible for prostate cancer screening. 2010. PMID:.
186 McInerney-Leo A, Biesecker BB, Hadley DW, et al. BRCA1/2 testing in hereditary breast and ovarian cancer families: effectiveness of problem-solving training as a counseling intervention. American journal of medical genetics Part A. Oct. 15. 2004;130A(3):221-7. [pmid: 15378542].
187 Morera OF, Castro FG. Important considerations in conducting statistical mediation analyses. American journal of public health. Mar. 2013;103(3):394-6. [pmid: 23327275].
188 Peate M, Meiser B, Cheah BC, et al. Making hard choices easier: a prospective, multicentre study to assess the efficacy of a fertility-related decision aid in young women with early-stage breast cancer. British journal of cancer. Mar. 13. 2012;106(6):1053-61. [pmid: 22415294].
189 PR C. The decision. Cutis. 1988;42(4):283-4. PMID:. [pmid: 3234027].
190 Rapport F, Iredale R, Jones W, et al. Decision aids for familial breast cancer: exploring women's views using focus groups. Health expectations: an international journal of public participation in health care and health policy. Sep. 2006;9(3):232-44. [pmid: 16911137].
191 Reuland DS, Pignone M. Improving the quality of decision-making processes for prostate cancer screening: progress and challenges. JAMA internal medicine. Oct. 14. 2013;173(18):1713-4. [pmid: 23897402].
192 Rueth NM, McMahon M, Arrington AK, et al. Preoperative risk assessment among women undergoing bilateral prophylactic mastectomy for cancer risk reduction. Annals of surgical oncology. Sep. 2011;18(9):2515-20. [pmid: 21424371].
193 Rupert DJ, Squiers LB, Renaud JM, et al. Communicating risk of hereditary breast and ovarian cancer with an interactive decision support tool. Patient education and counseling. Aug. 2013;92(2):188-96. [pmid: 23664232].
194 Sajid S, Mohile SG, Szmulewitz R, et al. Individualized decision-making for older men with prostate cancer: balancing cancer control with treatment consequences across the clinical spectrum. Seminars in oncology. Apr. 2011;38(2):309-25. [pmid: 21421119].
195 Schonberg MA, Hamel MB, Davis RB, et al. Development and evaluation of a decision aid on mammography screening for women 75 years and older. JAMA internal medicine. Mar. 2014;174(3):417-24. [pmid: 24378846].
196 Shabason J, Mao J, Frankel E, et al. The Role of Shared Decision Making in Patient Experiences in Radiation Oncology. International journal of radiation oncology, biology, physics. 2013;87(2 Supplement):S180-S1. PMID:.
197 Song L, Chen RC, Bensen JT, et al. Who makes the decision regarding the treatment of clinically localized prostate cancer--the patient or physician?: results from a population-based study. Cancer. Jan. 15. 2013;119(2):421-8. [pmid: 22786794].
198 Tong A, Kelly S, Nusbaum R, et al. Intentions for risk-reducing surgery among high-risk women referred for BRCA1/BRCA2 genetic counseling. Psycho-oncology. 2014. May. 17. [pmid: 24839250].
199 van den Bergh KA, Essink-Bot ML, van Klaveren RJ, et al. Informed decision making does not affect health-related quality of life in lung cancer screening (NELSON trial). Eur J Cancer. Dec. 2010;46(18):3300-6. [pmid: 20580546].
200 van Tol-Geerdink JJ, Leer JW, van Lin EN, et al. Offering a treatment choice in the irradiation of prostate cancer leads to better informed and more active patients, without harm to well-being. International journal of radiation oncology, biology, physics. Feb. 1. 2008;70(2):442-8. [pmid: 17765404].
201 van Vugt HA, Roobol MJ, Venderbos LD, et al. Informed decision making on PSA testing for the detection of prostate cancer: an evaluation of a leaflet with risk indicator. Eur J Cancer. Feb. 2010;46(3):669-77. [pmid: 20022239].
202 Volk RJ, Spann SJ. Decision-aids for prostate cancer screening. The Journal of family practice. May. 2000;49(5):425-7. [pmid: 10836773].
203 Watts KJ, Meiser B, Mitchell G, et al. How should we discuss genetic testing with women newly diagnosed with breast cancer? Design and implementation of a randomized controlled trial of two models of delivering education about treatment-focused genetic testing to younger women newly diagnosed with breast cancer. BMC cancer. 2012;12:320. [pmid: 22838957].
204 Wegwarth O, Kurzenhauser-Carstens S, Gigerenzer G. Overcoming the knowledge-behavior gap: The effect of evidence-based HPV vaccination leaflets on understanding, intention, and actual vaccination decision. Vaccine. Mar. 10. 2014;32(12):1388-93. [pmid: 24486360].
205 Wevers MR, Ausems MG, Verhoef S, et al. Behavioral and psychosocial effects of rapid genetic counseling and testing in newly diagnosed breast cancer patients: design of a multicenter randomized clinical trial. BMC cancer. 2011;11:6. [pmid: 21219598].
206 Williams RD. Patient decisions must focus on studies. Urology Times. 2010;38(1):4. Language: English. Entry Date: 20100226. Revision Date: 20100226. Publication Type: journal article.
207 12th international meeting on psychosocial aspects of hereditary cancer (IMPAHC). Familial Cancer. 2011. 04. 01. 2011;10(2):69-97. PMID:.
208 Ahmed SYt. A piece of my mind. Tie it and trust. JAMA: the journal of the American Medical Association. Oct. 19. 2005;294(15):1873-4. [pmid: 16234487].
209 Back A, Baile W. Communication skills: myths, realities, and new developments. The journal of supportive oncology. Sep-Oct. 2003;1(3):169-71. [pmid: 15334873].
210 Back AL, Arnold RM. Discussing prognosis: “how much do you want to know?” talking to patients who are prepared for explicit information. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Sep. 1. 2006;24(25):4209-13. [pmid: 16943539].
211 Belkora JK, Teng A, Volz S, et al. Expanding the reach of decision and communication aids in a breast care center: a quality improvement study. Patient education and counseling. May. 2011;83(2):234-9. [pmid: 20696543].
212 Isebaert S, Van Audenhove C, Haustermans K, et al. Evaluating a decision aid for patients with localized prostate cancer in clinical practice. Urologia internationalis. 2008;81(4):383-8. [pmid: 19077396].
213 Meiser B, Mann GJ, Watts KJ, et al. Prostate cancer screening decision aid. Fam Cancer. 2011;10:S93-S4. PMID:.
214 Skinner CS, Pollak KI, Farrell D, et al. Use of and reactions to a tailored CD-ROM designed to enhance oncologist-patient communication: the SCOPE trial intervention. Patient education and counseling. Oct. 2009;77(1):90-6. [pmid: 19321287].
215 Atassi K, Nemeth L, Edlund B, et al. Adapting the PPRNet TRIP QI Model to Increase Colorectal Cancer Screening in Primary Care. Journal of Cancer Therapy. 2012;3(6):866-73. PMID:.
216 Atlas SJ, Grant RW, Lester WT, et al. A cluster-randomized trial of a primary care informatics-based system for breast cancer screening. Journal of general internal medicine. Feb. 2011;26(2):154-61. [pmid: 20872083].
217 Baena Canada JM, Ramirez Daffos P, Diaz Diaz V, et al. Experience with a simplified format of decision making tool adjuvant! Online in breast cancer patients. Revista de calidad asistencial: organo de la Sociedad Espanola de Calidad Asistencial. Jul-Aug. 2010;25(4):228-31. [pmid: 20347375].
218 Ballinger R, Ford E, Pennery E, et al. Specialist breast care and research nurses' attitudes to adjuvant chemotherapy in older women with breast cancer. European journal of oncology nursing: the official journal of European Oncology Nursing Society. Feb. 2012;16(1):78-86. [pmid: 21550850].
219 Bernhard J, Butow P, Aldridge J, et al. Communication about standard treatment options and clinical trials: can we teach doctors new skills to improve patient outcomes?. Psycho-oncology. Dec. 2012;21(12):1265-74. [pmid: 23208837].
220 Bonvicini KA, Perlin MJ, Bylund CL, et al. Impact of communication training on physician expression of empathy in patient encounters. Patient education and counseling. Apr. 2009;75(1):3-10. [pmid: 19081704].
221 Brackett C, Kearing S, Cochran N, et al. Strategies for distributing cancer screening decision aids in primary care. Patient education and counseling. Feb. 2010;78(2):166-8. [pmid: 19665338].
222 Brothers BM, Easley A, Salani R, et al. Do survivorship care plans impact patients' evaluations of care? A randomized evaluation with gynecologic oncology patients. Gynecologic oncology. Jun. 2013;129(3):554-8. [pmid: 23474344].
223 Butow P, Cockburn J, Girgis A, et al. Increasing oncologists' skills in eliciting and responding to emotional cues: evaluation of a communication skills training program. Psycho-oncology. Mar. 2008;17(3):209-18. [pmid: 17575560].
224 Bylund CL, Brown R, Gueguen JA, et al. The implementation and assessment of a comprehensive communication skills training curriculum for oncologists. Psycho-oncology. Jun. 2010;19(6):583-93. [pmid: 19484714].
225 Choy ET, Chiu A, Butow P, et al. A pilot study to evaluate the impact of involving breast cancer patients in the multidisciplinary discussion of their disease and treatment plan. Breast. Apr. 2007;16(2):178-89. [pmid: 17158048].
226 Cousino M, Hazen R, Yamokoski A, et al. Parent participation and physician-parent communication during informed consent in child leukemia. Pediatrics. Dec. 2011;128(6):e1544-51. [pmid: 22065265].
227 Cunich M, Salkeld G, Dowie J, et al. Integrating evidence and individual preferences using a web-based multi-criteria decision analytic tool: an application to prostate cancer screening. The patient. 2011;4(3):153-62. [pmid: 21766911].
228 De Morgan SE, Butow PN, Lobb EA, et al. Development and pilot testing of a communication aid to assist clinicians to communicate with women diagnosed with ductal carcinoma in situ (DCIS). Supportive care in cancer: official journal of the Multinational Association of Supportive Care in Cancer. May. 2011;19(5):717-23. [pmid: 21088858].
229 de Visser M, Fluit C, Timmer-Bonte J, et al. Teaching adjuvant endocrine breast cancer treatment to medical students. The Netherlands journal of medicine. May. 2013;71(4):215-9. [pmid: 23723119].
230 Dimoska A, Butow PN, Lynch J, et al. Implementing patient question-prompt lists into routine cancer care. Patient education and counseling. Feb. 2012;86(2):252-8. [pmid: 21741195].
231 Edwards A, Elwyn G, Hood K, et al. Patient-based outcome results from a cluster randomized trial of shared decision making skill development and use of risk communication aids in general practice. Family practice. Aug. 2004;21(4):347-54. [pmid: 15249521].
232 Elstein AS. Framing effects. Medical decision making: an international journal of the Society for Medical Decision Making. Apr-Jun. 1990;10(2):148. [pmid: 2348755].
233 Elwyn G, Edwards A, Hood K, et al. Achieving involvement: process outcomes from a cluster randomized trial of shared decision making skill development and use of risk communication aids in general practice. Family practice. Aug. 2004;21(4):337-46. [pmid: 15249520].
234 Emery J, Morris H, Goodchild R, et al. The GRAIDS Trial: a cluster randomised controlled trial of computer decision support for the management of familial cancer risk in primary care. British journal of cancer. Aug. 20. 2007;97(4):486-93. [pmid: 17700548].
235 Farah SS, Winter M, Appu S. Helping doctors utilize the prostate-specific antigen effectively: an online randomized controlled trial (The DUPE trial). ANZ journal of surgery. Sep. 2012;82(9):633-8. [pmid: 22900524].
236 Girgis A, Breen S, Stacey F, et al. Impact of two supportive care interventions on anxiety, depression, quality of life, and unmet needs in patients with nonlocalized breast and colorectal cancers. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Dec. 20. 2009;27(36):6180-90. [pmid: 19917842].
237 Girgis A, Cockburn J, Butow P, et al. Improving patient emotional functioning and psychological morbidity: evaluation of a consultation skills training program for oncologists. Patient education and counseling. Dec. 2009;77(3):456-62. [pmid: 19819660].
238 Goodman N. In the public's view… screening but not seeing. British journal of hospital medicine. 1997;57(5):201. PMID:. [pmid: 9176597].
239 Gyomber D, Lawrentschuk N, Wong P, et al. Improving informed consent for patients undergoing radical prostatectomy using multimedia techniques: a prospective randomized crossover study. BJU international. Oct. 2010;106(8):1152-6. [pmid: 20346048].
240 Hack TF, Ruether JD, Weir LM, et al. Promoting consultation recording practice in oncology: identification of critical implementation factors and determination of patient benefit. Psycho-oncology. Jun. 2013;22(6):1273-82. [pmid: 22821445].
241 Hannan TJ, Vincenz M. Introduction of a computer-based oncology patient-care system in a teaching hospital. The Medical journal of Australia. Mar. 7. 1988;148(5):242-7. [pmid: 3343955].
242 Haskard KB, Williams SL, DiMatteo MR, et al. Physician and patient communication training in primary care: effects on participation and satisfaction. Health psychology: official journal of the Division of Health Psychology, American Psychological Association. Sep. 2008;27(5):513-22. [pmid: 18823177].
243 Heyn L, Finset A, Eide H, et al. Effects of an interactive tailored patient assessment on patient-clinician communication in cancer care. Psycho-oncology. Jan. 2013;22(1):89-96. [pmid: 21919122].
244 Hines C, Bingham J, Muirden N, et al. Cancer pain management. Improving knowledge and patient care. Australian family physician. Jul. Suppl 2. 1998;27:S66-9. [pmid: 9679357].
245 Hoffman RM, Helitzer DL. Moving towards shared decision making in prostate cancer screening. Journal of general internal medicine. Jul. 2007;22(7):1056-7. [pmid: 17364242].
246 Hofmann S, Vetter J, Wachter C, et al. Visual AIDS for multimodal treatment options to support decision making of patients with colorectal cancer. BMC medical informatics and decision making. 2012;12:118. [pmid: 23092310].
247 Hulsman RL, Ros WJ, Winnubst JA, et al. The effectiveness of a computer-assisted instruction programme on communication skills of medical specialists in oncology. Medical education. Feb. 2002;36(2):125-34. [pmid: 11869439].
248 Jenkins V, Solis-Trapala I, Langridge C, et al. What oncologists believe they said and what patients believe they heard: an analysis of phase I trial discussions. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Jan. 1. 2011;29(1):61-8. [pmid: 21098322].
249 Jones JM, Papadakos J, Bennett C, et al. Maximizing your Patient Education Skills (MPES): a multi-site evaluation of an innovative patient education skills training course for oncology health care professionals. Patient education and counseling. Aug. 2011;84(2):176-84. [pmid: 20822877].
250 Kripalani S, Sharma J, Justice E, et al. Low-literacy interventions to promote discussion of prostate cancer: a randomized controlled trial. American journal of preventive medicine. Aug. 2007;33(2):83-90. [pmid: 17673094].
251 Livingston P, White V, Hayman J, et al. How acceptable is a referral and telephone-based outcall programme for men diagnosed with cancer? A feasibility study. European journal of cancer care. Dec. 2006;15(5):467-75. [pmid: 17177905].
252 Markman M, Petersen J, Montgomery R. An examination of characteristics of lung and colon cancer patients participating in a web-based decision support program. Oncology. 2005;69(4):311-6. PMID:. [pmid: 16293971].
253 McQueen A, Bartholomew LK, Greisinger AJ, et al. Behind closed doors: physician-patient discussions about colorectal cancer screening. Journal of general internal medicine. Nov. 2009;24(11):1228-35. [pmid: 19763699].
254 Molenaar S, Sprangers MA, Rutgers EJ, et al. Decision support for patients with early-stage breast cancer: effects of an interactive breast cancer CDROM on treatment decision, satisfaction, and quality of life. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Mar. 15. 2001;19(6):1676-87. [pmid: 11250997].
255 Orzano AJ, Ohman-Strickland PA, Patel M. What can family medicine practices do to facilitate knowledge management?. Health care management review. Jul-Sep. 2008;33(3):216-24. [pmid: 18580301].
256 Park S, Chang S, Chung C. Effects of a cognition-emotion focused program to increase public participation in Papanicolaou smear screening. Public Health Nurs. Jul-Aug. 2005;22(4):289-98. [pmid: 16150010].
257 Pidala J, Craig BM, Lee SJ, et al. Practice variation in physician referral for allogeneic hematopoietic cell transplantation. Bone marrow transplantation. Jan. 2013;48(1):63-7. [pmid: 22705801].
258 Pieterse AH, Henselmans I, de Haes HC, et al. Shared decision making: prostate cancer patients' appraisal of treatment alternatives and oncologists' eliciting and responding behavior, an explorative study. Patient education and counseling. Dec. 2011;85(3):e251-9. [pmid: 21658883].
259 Pit S, Cockburn J. Cancer Information Services: a pre-/post-evaluation of training to promote nationwide consistency of information. European journal of cancer care. Dec. 2000;9(4):204-11. [pmid: 11829367].
260 Price-Haywood EG, Roth KG, Shelby K, et al. Cancer risk communication with low health literacy patients: a continuing medical education program. Journal of general internal medicine. May. Suppl 2. 2010;25:S126-9. [pmid: 20352506].
261 Prior A. Personal view. Br Med J (Clin Res Ed). Oct. 10. 1987;295(6603):920. [pmid: 11658887].
262 Quinn GP, Vadaparampil ST, Gwede CK, et al. Developing a referral system for fertility preservation among patients with newly diagnosed cancer. Journal of the National Comprehensive Cancer Network: JNCCN. Nov. 2011;9(11):1219-25. [pmid: 22056654].
263 Rayl. Before signing on the dotted line. Mamm. 2005;(nov/dec):50-1. PMID:.
264 Ruland CM, Bakken S. Developing, implementing, and evaluating decision support systems for shared decision making in patient care: a conceptual model and case illustration. Journal of biomedical informatics. Oct-Dec. 2002;35(5-6):313-21. [pmid: 12968780].
265 Sabbioni ME. Informing cancer patients: whose truth matters?. Annals of the New York Academy of Sciences. Feb. 20. 1997;809:508-13. [pmid: 9103601].
266 Salkeld GP, Young JM, Solomon MJ. Consumer choice and the National Bowel Cancer Screening Program. The Medical journal of Australia. Jun. 5. 2006;184(11):541-2. [pmid: 16768656].
267 Sepucha KR, Belkora JK, Aviv C, et al. Improving the quality of decision making in breast cancer: consultation planning template and consultation recording template. Oncology nursing forum. Jan-Feb. 2003;30(1):99-106. [pmid: 12515987].
268 Sepucha KR, Belkora JK, Tripathy D, et al. Building bridges between physicians and patients: results of a pilot study examining new tools for collaborative decision making in breast cancer. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Mar. 2000;18(6):1230-8. [pmid: 10715292].
269 Shankaran V, Luu TH, Nonzee N, et al. Costs and cost effectiveness of a health care provider-directed intervention to promote colorectal cancer screening. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Nov. 10. 2009;27(32):5370-5. [pmid: 19826133].
270 Sharp L, Laurell G, Tiblom Y, et al. Care diaries: a way of increasing head and neck cancer patient's involvement in their own care and the communication between clinicians. Cancer nursing. Mar-Apr. 2004;27(2):119-26. [pmid: 15253169].
271 Shepherd HL, Barratt A, Trevena LJ, et al. Three questions that patients can ask to improve the quality of information physicians give about treatment options: a cross-over trial. Patient education and counseling. Sep. 2011;84(3):379-85. [pmid: 21831558].
272 Stacey D, O'Connor AM, Graham ID, et al. Randomized controlled trial of the effectiveness of an intervention to implement evidence-based patient decision support in a nursing call centre. Journal of telemedicine and telecare. 2006;12(8):410-5. [pmid: 17227607].
273 Stacey D, Samant R, Pratt M, et al. Feasibility of training oncology residents in shared decision making: a pilot study. Journal of cancer education: the official journal of the American Association for Cancer Education. Jun. 2012;27(3):456-62. [pmid: 22539055].
274 Surbone A. Truth-telling, risk, and hope. Annals of the New York Academy of Sciences. Feb. 20. 1997;809:72-9. [pmid: 9103558].
275 Tanida N. Japanese attitudes towards truth disclosure in cancer. Scandinavian journal of social medicine. Mar. 1994;22(1):50-7. [pmid: 8029667].
276 Tattersall M, Ellis P. Ethical debate. Truth, the first casualty. Communication is a vital part of care. BMJ. Jun. 20. 1998;316(7148):1891-2. [pmid: 9669846].
277 Thompson RS, Michnich ME, Gray J, et al. Maximizing compliance with hemoccult screening for colon cancer in clinical practice. Medical care. Oct. 1986;24(10):904-14. [pmid: 3762240].
278 Timmermans LM, van der Maazen RW, van Spaendonck KP, et al. Enhancing patient participation by training radiation oncologists. Patient education and counseling. Oct. 2006;63(1-2):55-63. [pmid: 16644175].
279 Turner SL, Maher EJ. Information and choice in decisions about cancer treatment. BMJ. Oct. 8. 1994;309(6959):955. [pmid: 7950679].
280 Uchitomi Y, Yamawaki S. Truth-telling practice in cancer care in Japan. Annals of the New York Academy of Sciences. Feb. 20. 1997;809:290-9. [pmid: 9103580].
281 Volk RJ, Linder SK, Kallen MA, et al. Primary care physicians' use of an informed decision-making process for prostate cancer screening. Annals of family medicine. Jan-Feb. 2013;11(1):67-74. [pmid: 23319508].
282 Walker MS, Podbilewicz-Schuller Y. Video preparation for breast cancer treatment planning: results of a randomized clinical trial. Psycho-oncology. May. 2005;14(5):408-20. [pmid: 15386757].
283 Wilson BJ, Torrance N, Mollison J, et al. Cluster randomized trial of a multifaceted primary care decision-support intervention for inherited breast cancer risk. Family practice. Oct. 2006;23(5):537-44. [pmid: 16787957].
284 Yap TY, Yamokoski A, Noll R, et al. A physician-directed intervention: teaching and measuring better informed consent. Academic medicine: journal of the Association of American Medical Colleges. Aug. 2009;84(8):1036-42. [pmid: 19638769].
285 Young JM, Ward JE. Randomised trial of intensive academic detailing to promote opportunistic recruitment of women to cervical screening by general practitioners. Australian and New Zealand journal of public health. 2003;27(3):273-81. [pmid: 14705281].
286 Bhatnagar V, Frosch DL, Tally SR, et al. Evaluation of an internet-based disease trajectory decision tool for prostate cancer screening. Value in health: the journal of the International Society for Pharmacoeconomics and Outcomes Research. Jan-Feb. 2009;12(1):101-8. [pmid: 18637139].
287 Hacking B, Wallace L, Scott S, et al. Testing the feasibility, acceptability and effectiveness of a ‘decision navigation’ intervention for early stage prostate cancer patients in Scotland--a randomised controlled trial. Psycho-oncology. May. 2013;22(5):1017-24. [pmid: 22570252].
288 Jerant A, Kravitz RL, Fiscella K, et al. Effects of tailored knowledge enhancement on colorectal cancer screening preference across ethnic and language groups. Patient education and counseling. Jan. 2013;90(1):103-10. [pmid: 22985627].
289 Korfage IJ, Fuhrel-Forbis A, Ubel PA, et al. Informed choice about breast cancer prevention: randomized controlled trial of an online decision aid intervention. Breast cancer research: BCR. Sep. 3. 2013;15(5):R74. [pmid: 24004815].
290 Lam WW, Chan M, Or A, et al. Reducing treatment decision conflict difficulties in breast cancer surgery: a randomized controlled trial. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Aug. 10. 2013;31(23):2879-85. [pmid: 23835709].
291 Meropol NJ, Egleston BL, Buzaglo JS, et al. A Web-based communication aid for patients with cancer: the CONNECT Study. Cancer. Apr. 1. 2013;119(7):1437-45. [pmid: 23335150].
292 Smith SK, Simpson JM, Trevena LJ, et al. Factors Associated with Informed Decisions and Participation in Bowel Cancer Screening among Adults with Lower Education and Literacy. Medical decision making: an international journal of the Society for Medical Decision Making. Jan. 13. 2014;34(6):756-72. [pmid: 24421292].
293 Stalmeier PF, Roosmalen MS. Concise evaluation of decision aids. Patient education and counseling. Jan. 2009;74(1):104-9. [pmid: 18775622].
294 Steckelberg A, Haastert B, Hulfenhaus C, et al. Effect of Evidence-Based Risk Information on “Informed Choice” in Colorectal Cancer Screening: Randomised Controlled Trial. Gesundheitswesen. 2013. Apr. 3. [pmid: 23553186].
295 Taylor KL, Williams RM, Davis K, et al. Decision making in prostate cancer screening using decision aids vs usual care: a randomized clinical trial. JAMA internal medicine. Oct. 14. 2013;173(18):1704-12. [pmid: 23896732].
296 van Tol-Geerdink JJ, Willem Leer J, Weijerman PC, et al. Choice between prostatectomy and radiotherapy when men are eligible for both: a randomized controlled trial of usual care vs decision aid. BJU international. Apr. 2013;111(4):564-73. [pmid: 22882966].
297 Lin GA, Halley M, Rendle KA, et al. An effort to spread decision aids in five California primary care practices yielded low distribution, highlighting hurdles. Health Aff (Millwood). Feb. 2013;32(2):311-20. [pmid: 23381524].
298 Abendroth A, Bauer S. Adjuvant chemotherapy for soft tissue sarcoma? a clear no - well - yes-ish. Dtsch Med Wochenschr. Oct. 2013;138(41):2107-10. [pmid: 24085368].
299 Betzler M. The informed cancer patient. Knowledge enables sound decisions to be made. MMW Fortschritte der Medizin. Dec. 7. 2006;148(49-50):30-1. [pmid: 17619323].
300 Burkert S, Knoll N. Dyadische Planungsintervention nach Prostatektomie. Psychotherapeut. 2012;57(6):525-30. PMID:.
301 Hamaguchi K. Role of nursing informed consent. Hokkaido igaku zasshi. The Hokkaido journal of medical science. Jan. 1998;73(1):21-5. [pmid: 9546141].
302 Hilfrich J, Janicke F. Therapy decision - patient participation?. Onkologie. Dec. Suppl 5. 2002;25:25-7. [pmid: 23573618].
303 Kopke S, Gerlach A. Informed decisions. Pflege Zeitschrift. Apr. 2012;65(4):220-3. [pmid: 22571043].
304 Milliat-Guittard L, Romestaing P, Letrilliart L, et al. Patient-held health records: impact on breast cancer follow-up in the Rhone-Alpes region. Project Archimed. Revue d'epidemiologie et de sante publique. Jul. Suppl 3. 2008;56:S239-46. [pmid: 18538965].
305 Muller KR, Bonamigo RR, Crestani TA, et al. Evaluation of patients' learning about the ABCD rule: A randomized study in southern Brazil. Anais brasileiros de dermatologia. Nov-Dec. 2009;84(6):593-8. [pmid: 20191170].
306 Rasky E, Groth S. Information materials on mammography screening in Austria--do they help women with informed decision?. Sozial- und Praventivmedizin. 2004;49(6):391-7. [pmid: 15669439].
307 Sawada S, Yamashita M, Komori E, et al. Current status of adjuvant chemotherapy for resected lung cancer at our institute--focus on clinical trial enrollment. Gan to kagaku ryoho Cancer & chemotherapy. Mar. 2010;37(3):439-42. [pmid: 20332679].
308 Schneck H. A dialogue on key issues. Krankenpflege Soins infirmiers. 2011;104(7):44-6. [pmid: 21797188].
309 Schulze-Rath R, Husmann G, Kaiser M, et al. Use and evaluation of a decision aid for patients with T1 stage breast cancer. Geburtshilfe und Frauenheilkunde. 2009;69(5):406-12. PMID:.
310 Vodermaier A, Caspari C, Kohm J, et al. Shared decision-making in primary breast cancer. Zeitschrift fur arztliche Fortbildung und Qualitatssicherung. Mar. 2004;98(2):127-33. [pmid: 15106493].
311 Brenner A, Howard K, Lewis C, et al. Comparing 3 values clarification methods for colorectal cancer screening decision-making: a randomized trial in the US and Australia. Journal of general internal medicine. Mar. 2014;29(3):507-13. [pmid: 24272830].
312 Gray SW, Hornik RC, Schwartz JS, et al. The impact of risk information exposure on women's beliefs about direct-to-consumer genetic testing for BRCA mutations. Clinical genetics. Jan. 2012;81(1):29-37. [pmid: 21992449].
313 Gray SW, O'Grady C, Karp L, et al. Risk information exposure and direct-to-consumer genetic testing for BRCA mutations among women with a personal or family history of breast or ovarian cancer. Cancer epidemiology, biomarkers & prevention: a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. Apr. 2009;18(4):1303-11. [pmid: 19318436].
314 Perneger TV, Schiesari L, Cullati S, et al. Does information about risks and benefits improve the decision-making process in cancer screening - randomized study. Cancer epidemiology. Dec. 2011;35(6):574-9. [pmid: 21622043].
315 Vickers AJ, Elkin EB, Peele PB, et al. Long-term health outcomes of a decision aid: data from a randomized trial of adjuvant! In women with localized breast cancer. Medical decision making: an international journal of the Society for Medical Decision Making. Jul-Aug. 2009;29(4):461-7. [pmid: 19270108].
316 Zikmund-Fisher BJ, Fagerlin A, Ubel PA. A demonstration of “less can be more” in risk graphics. Medical decision making: an international journal of the Society for Medical Decision Making. Nov-Dec. 2010;30(6):661-71. [pmid: 20375419].
317 Huang RC, Auvinen A, Hakama M, et al. Effect of intervention on decision making of treatment for disease progression, prostate-specific antigen biochemical failure and prostate cancer death. Health expectations: an international journal of public participation in health care and health policy. 2012. Jul. 19. [pmid: 22809163].
318 Kassan EC, Williams RM, Kelly SP, et al. Men's use of an Internet-based decision aid for prostate cancer screening. Journal of health communication. 2012;17(6):677-97. [pmid: 21919646].
319 McCaffery KJ, Irwig L, Chan SF, et al. HPV testing versus repeat Pap testing for the management of a minor abnormal Pap smear: evaluation of a decision aid to support informed choice. Patient education and counseling. Dec. 2008;73(3):473-9. 81. [pmid: 18757164].
320 Anderson C, Carter J, Nattress K, et al. “The booklet helped me not to panic”: a pilot of a decision aid for asymptomatic women with ovarian cancer and with rising CA-125 levels. International journal of gynecological cancer: official journal of the International Gynecological Cancer Society. May. 2011;21(4):737-43. [pmid: 21412158].
321 Best of the Best Posters Listing. Asia-Pacific Journal of Clinical Oncology. 2011;7:51-2. PMID:.
322 Screening: tell the truth. Prescrire international. Apr. 2012;21(126):88. [pmid: 22515131].
323 Banegas MMP. Prediction, Communication, and Distribution of Breast Cancer Risk. 2012.
324 Bekker HL. Decision aids and uptake of screening. BMJ. 2010;341:c5407. [pmid: 20978061].
325 Berry DL, Halpenny B, Chang P, et al., editors. Health literacy screening prior to education for patients with cancer. JOURNAL OF CLINICAL ONCOLOGY. 2013. AMER SOC CLINICAL ONCOLOGY 2318 MILL ROAD, STE 800, ALEXANDRIA, VA 22314 USA.
326 Brown RF, Butow PN, Sharrock MA, et al. Education and role modelling for clinical decisions with female cancer patients. Health expectations: an international journal of public participation in health care and health policy. Dec. 2004;7(4):303-16. [pmid: 15544683].
327 Brundage MD. Is seeing believing?. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Feb. 10. 2010;28(5):711-3. [pmid: 20065182].
328 Budden L. Assisting women's treatment decisions. Aust Nurs J. Mar. 2004;11(8):39. [pmid: 19157395].
329 Cady B, Chung MA. Re: “Pilot trial of a computerized decision aid for breast cancer prevention”. The breast journal. Sep-Oct. 2007;13(5):539-40. author reply 40-2. [pmid: 17760687].
330 Cain JM. Still learning how to listen to patients. Gynecologic oncology. Feb. 2003;88(2):87-8. [pmid: 12586584].
331 Chambers SK, Ferguson M, Gardiner RA, et al. ProsCan for men: randomised controlled trial of a decision support intervention for men with localised prostate cancer. BMC cancer. 2008;8:207. [pmid: 18651985].
332 Charles C, Gafni A, Whelan T. Self-reported use of shared decision-making among breast cancer specialists and perceived barriers and facilitators to implementing this approach. Health expectations: an international journal of public participation in health care and health policy. Dec. 2004;7(4):338-48. [pmid: 15544686].
333 Davison BJ, Goldenberg SL. Decisional regret and quality of life after participating in medical decision-making for early-stage prostate cancer. BJU international. Jan. 2003;91(1):14-7. [pmid: 12614242].
334 Dorcy KKS. Hope as a Discursive Practice in Cancer Research Decision-making: College of Nursing. University of Utah. 2011.
335 Duncan A, Zajac I, Wilson C, et al. Study protocol: Optimising men's uptake of faecal occult blood test screening for bowel cancer: A population based randomised controlled trial. Asia Pac J Clin Oncol. 2012;8:310-1. PMID:.
336 Eccles BK, Cross W, Rosario DJ, et al. SABRE 1 (Surgery Against Brachytherapy - a Randomised Evaluation): feasibility randomised controlled trial (RCT) of brachytherapy vs radical prostatectomy in low-intermediate risk clinically localised prostate cancer. BJU international. Aug. 2013;112(3):330-7. [pmid: 23826842].
337 Entwistle V. Supporting participation in clinical research: decision aids for trial recruitment?. Health expectations: an international journal of public participation in health care and health policy. Sep. 2008;11(3):205-7. [pmid: 18816317].
338 Fairfield K, Gerstein B, Levin CA, et al., editors. DECISIONS ABOUT MEDICATION USE AND CANCER SCREENING AMONG ELDERLY ADULTS IN THE UNITED STATES. Journal of general internal medicine. 2013. SPRINGER 233 SPRING ST, NEW YORK, NY 10013 USA.
339 Fenton JJ. A decision aid to enhance informed decision making about bowel cancer screening improved knowledge but reduced screening uptake. Evidence-based medicine. Jun. 2011;16(3):78-9. [pmid: 21252161].
340 Fowble B, Belkora J, Volz S, et al. Implementing Patient-Oriented Decision Support Into Breast Cancer Care. International journal of radiation oncology, biology, physics. 2013;87(2 Supplement):S39-S40. PMID:.
341 Friesen RW. Involving surgeons in discussions of breast cancer surgery. CMAJ: Canadian Medical Association journal = journal de l'Association medicale canadienne. Sep. 15. 1994;151(6):732. 4. 6. [pmid: 8087747].
342 Geng ZZ, Tong L, Ahn C, et al. Mo1088 Influence of Race and Ethnicity on Response to Fecal Immunochemical Test Outreach Colonoscopy Outreach and Usual Care As Part of a Randomized Controlled Trial in a Safety-Net Setting. Gastroenterology. 2013;144(5):S-573. PMID:.
343 Geng ZZ, Tong L, Ahn C, et al. Influence of race and ethnicity on response to fecal immunochemical test outreach, colonoscopy outreach, and usual care as part of a randomized controlled trial in a safety-net setting. Gastroenterology. 2013;144(5):S573. PMID:.
344 Ghavamzadeh A, Bahar B. Communication with the cancer patient in Iran. Information and truth. Annals of the New York Academy of Sciences. Feb. 20. 1997;809:261-5. [pmid: 9103577].
345 Harralson T, Toche-Manley L, Dietzen L, et al., editors. Development and Implementation of an Automated Distress Management System for Cancer Patients. Psycho-oncology. 2013. WILEY-BLACKWELL 111 RIVER ST, HOBOKEN 07030-5774, NJ USA.
346 Henneman L, Oosterwijk JC, van Asperen CJ, et al. The effectiveness of a graphical presentation in addition to a frequency format in the context of familial breast cancer risk communication: a multicenter controlled trial. BMC medical informatics and decision making. 2013;13:55. [pmid: 23627498].
347 Henselmans I, de Haes HC, Smets EM. Enhancing patient participation in oncology consultations: a best evidence synthesis of patient-targeted interventions. Psycho-oncology. May. 2013;22(5):961-77. [pmid: 22585543].
348 Hietanen PS, Aro AR, Holli KA, et al. A short communication course for physicians improves the quality of patient information in a clinical trial. Acta Oncol. 2007;46(1):42-8. [pmid: 17438704].
349 Hoerni B. Cancer patients' participation in medical decisions. Bulletin du cancer. Oct. 2002;89(10):904-7. [pmid: 12441283].
350 Hoffman JR, Wilkes MS, Day FC, et al. The roulette wheel: an aid to informed decision making. PLoS medicine. Jun. 2006;3(6):e137. [pmid: 16752950].
351 Hoffman-Censits JH, Petrich A, Quinn A, et al. Impact of a novel decision counseling program on treatment knowledge, decisional conflict, and choice in men with early-stage, low-risk prostate cancer. JOURNAL OF CLINICAL ONCOLOGY. 2013. AMER SOC CLINICAL ONCOLOGY 2318 MILL ROAD, STE 800, ALEXANDRIA, VA 22314 USA.
352 Holleb AI. Cancer therapy--the patient's choice? Presidential address. Cancer. Feb. 1974;33(2):301-2. [pmid: 4812751].
353 Honea N, Towsley GL, Caserta M, et al. The randomized preference design: tailoring learning preferences. Communicating Nursing Research. 2009;42:101. Language: English. Entry Date: 20101112. Revision Date: 20101112. Publication Type: journal article.
354 Hurria A. Communicating treatment options to older patients: challenges and opportunities. Journal of the National Comprehensive Cancer Network: JNCCN. Sep. 2012;10(9):1174-6. [pmid: 22956814].
355 Izquierdo F, Gracia J, Guerra M, et al. Health technology assessment-based development of a Spanish breast cancer patient decision aid. International journal of technology assessment in health care. Oct. 2011;27(4):363-8. [pmid: 22004778].
356 Jacobsen PB, Wells KJ, Meade CD, et al. Effects of a brief multimedia psychoeducational intervention on the attitudes and interest of patients with cancer regarding clinical trial participation: a multicenter randomized controlled trial. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Jul. 10. 2012;30(20):2516-21. [pmid: 22614993].
357 Jager GJ, Severens JL. Diagnostic strategy in uncertainty. Medical decision making: an international journal of the Society for Medical Decision Making. Jul-Sep. 2000;20(3):355-6. [pmid: 10929859].
358 Kaplan AL, Crespi CM, Saucedo J, Dahan E, Lambrechts S, Kaplan R, Saigal C. Predictors of decisional conflict in men with newly diagnosed prostate cancer: Baseline results from a shared decision-making trial. Journal of Urology. 2014;191(4):e144-e5. PMID:.
359 Kass NE, Sugarman J, Medley AM, et al. An intervention to improve cancer patients' understanding of early-phase clinical trials. Irb. May-Jun. 2009;31(3):1-10. [pmid: 19552233].
360 Katz SJ, Morrow M. Contralateral prophylactic mastectomy for breast cancer: addressing peace of mind. JAMA: the journal of the American Medical Association. Aug. 28. 2013;310(8):793-4. [pmid: 23907558].
361 Kay. Hope as a discursive practice in cancer research decision-making. University of Utah. 2011.
362 Kearsley JH. Therapeutic decision-making in clinical oncology: a matter of perspective. Australasian radiology. Feb. 1989;33(1):4-7. [pmid: 2712788].
363 Keefe CW, Thompson ME, Noel MM. Medical students, clinical preventive services, and shared decision-making. Academic medicine: journal of the Association of American Medical Colleges. Nov. 2002;77(11):1160-1. [pmid: 12431938].
364 Kepka DL. Preventing cervical cancer among US Latinas: HPV infection, HPV vaccine education, and HPV vaccine knowledge. 2010.
365 Kim SP, Karnes RJ, Nguyen PL, et al. Clinical implementation of quality of life instruments and prediction tools for localized prostate cancer: results from a national survey of radiation oncologists and urologists. The Journal of urology. Jun. 2013;189(6):2092-8. [pmid: 23219546].
366 Klocker JG, Klocker-Kaiser U, Schwaninger M. Truth in the relationship between cancer patient and physician. Annals of the New York Academy of Sciences. Feb. 20. 1997;809:56-65. [pmid: 9103556].
367 Lagios M. Therapeutic decisions for ductal carcinoma in situ: a Gordian knot. The breast journal. Mar-Apr. 2009;15(2):117-9. [pmid: 19292796].
368 Lee CJ, Gray SW, Lewis N. Internet use leads cancer patients to be active health care consumers. Patient education and counseling. Dec. Suppl. 2010;81:S63-9. [pmid: 20889279].
369 Lewis C, Pignone M, Schild LA, et al. Effectiveness of a patient- and practice-level colorectal cancer screening intervention in health plan members: design and baseline findings of the CHOICE trial. Cancer. Apr. 1. 2010;116(7):1664-73. [pmid: 20143439].
370 McClurg MM. The wounded healer: decisions, decisions. Humane medicine. Apr. 1994;10(2):132-5. [pmid: 11653132].
371 Mersereau J, editor. To Survive Without Regret: Fertility Preservation Decision Support. Psycho-oncology. 2013. WILEY-BLACKWELL 111 RIVER ST, HOBOKEN 07030-5774, NJ USA.
372 Mitsuya H. Telling the truth to cancer patients and patients with HIV-1 infection in Japan. Annals of the New York Academy of Sciences. Feb. 20. 1997;809:279-89. [pmid: 9103579].
373 Montgomery KK, Harris-Braun EK. Information is not enough: the place of statistics in the doctor-patient relationship. Cancer treatment and research. 2008;140:29-43. [pmid: 18283768].
374 Nattinger AB. Variation in the choice of breast-conserving surgery or mastectomy: patient or physician decision making?. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Aug. 20. 2005;23(24):5429-31. [pmid: 16110002].
375 Nitschke R. Physician-patient communication in phase I cancer trials. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Feb. 1. 2004;22(3):571-2. author reply 2-3. [pmid: 14752086].
376 Oates DJ, Silliman RA. Health literacy: improving patient understanding. Oncology (Williston Park). Apr. 15. 2009;23(4):376. 9. [pmid: 19476268].
377 Parker S, Zipursky J, Ma H, et al., editors. Randomized Controlled Trial Demonstrates a Web-based Multimedia Program Used Prior to First-Time Colonoscopy Decreased Patient Anxiety, Sedation Requirement, and Procedure Time While Increasing Knowledge. AMERICAN JOURNAL OF GASTROENTEROLOGY. 2013. NATURE PUBLISHING GROUP 75 VARICK ST, 9TH FLR, NEW YORK, NY 10013-1917 USA.
378 Partin MR, Powell AA. If less is more, which outcomes should be presented in facilitating prostate cancer screening decision making?. JAMA internal medicine. Sep. 23. 2013;173(17):1656-7. [pmid: 24061391].
379 Pasacreta JV. An empowerment information intervention improved participation in treatment decision making in men with recently diagnosed prostate cancer. Evidence Based Nursing. 1998;1(2):49. PMID:.
380 Plenary J. T uesday, 13 N ovember. 2012. PMID:.
381 Price-Haywood EG. Health information needs and predictors of cancer screening status among patients with limited health literacy. Cancer Epidemiology Biomarkers & Prevention. 2011;20(10 (suppl.)). PMID:.
382 Rowan KE, Sparks L, Pecchioni L, et al. The CAUSE model: a research-supported aid for physicians communicating with patients about cancer risk. Health communication. 2003;15(2):235-48. [pmid: 12742774].
383 Sawka AM, Straus S, Brierley JD, et al. Decision aid on radioactive iodine treatment for early stage papillary thyroid cancer--a randomized controlled trial. Trials. 2010;11:81. [pmid: 20659341].
384 Sawka AM, Straus S, Gafni A, et al. How can we meet the information needs of patients with early stage papillary thyroid cancer considering radioactive iodine remnant ablation?. Clinical endocrinology. Apr. 2011;74(4):419-23. [pmid: 21198742].
385 Scherer JS, Swidler MA. Decision-making in patients with cancer and kidney disease. Advances in chronic kidney disease. Jan. 2014;21(1):72-80. [pmid: 24359989].
386 Sciallero S, Sobrero A. Informed decisions regarding microsatellite instability testing: need for an intention-to-screen analysis. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Oct. 1. 2010;28(28):e537. author reply e8. [pmid: 20679625].
387 Stephenson A, Krebs T, Berglund R, Campbell S, Ciezki J, Fergany A, Gong M, Haber GP, Klein E, Stein R, Tendulkar R, Kattan M. Decision analysis model to facilitate treatment decision-making for localized prostate cancer: Results of a randomized trial. Journal of Urology. 2014;191(4):e663. PMID:.
388 ter Louwe L, ter Kuile M, Fischer M, et al., editors. DEVELOPMENT AND FIELD TEST OF A WEB-BASED PATIENT DECISION AID ABOUT FERTILITY PRESERVATION FOR BREAST CANCER PATIENTS. JOURNAL OF SEXUAL MEDICINE. 2013. WILEY-BLACKWELL 111 RIVER ST, HOBOKEN 07030-5774, NJ USA.
389 Uzzo RG, Wei JT. Prostate cancer and the educated consumer. Seminars in urologic oncology. Feb. 2002;20(1):1-2. [pmid: 11828351].
390 van Eys J. Children as decision makers. Journal of the Association of Pediatric Oncology Nurses. 1986;3(3):18-22. 30. [pmid: 3640816].
391 Vandenberg TA, Gustafson DH, Owens B, et al. Interaction between the breast cancer patient and the health care system: demands, constraints and options for the future. Cancer prevention & control: CPC = Prevention & controle en cancerologie: PCC. Jun. 1997;1(2):152-6. [pmid: 9765739].
392 Visser A, Prins JB, Hoogerbrugge N, et al. Group medical visits in the follow-up of women with a BRCA mutation: design of a randomized controlled trial. BMC women's health. 2011;11:39. [pmid: 21864353].
393 von Wagner C. A decision aid to support informed choice about bowel cancer screening in people with low educational level improves knowledge but reduces screening uptake. Evidence-based nursing. Apr. 2011;14(2):36-7. [pmid: 21421966].
394 Vordermark D. Patient information and decision AIDS in oncology: need for communication between patients and physicians. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Oct. 10. 2010;28(29):e567. author reply e8. [pmid: 20805457].
395 Waljee JF, Rogers MA, Alderman AK. Decision aids and breast cancer: do they influence choice for surgery and knowledge of treatment options?. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Mar. 20. 2007;25(9):1067-73. [pmid: 17369570].
396 Walter LC, Lewis CL. Maximizing informed cancer screening decisions. Archives of internal medicine. Oct. 22. 2007;167(19):2027-8. [pmid: 17954794].
397 Wang D, Sesay M, Tai C, et al. 135 VIDEO-BASED EDUCATIONAL TOOL IMPROVES PATIENT COMPREHENSION OF COMMON PROSTATE HEALTH TERMINOLOGY. The Journal of urology. 2013;189(4 Supplement):e54-e5. PMID:.
398 Watts KJ, Wakefield CE, Meiser B, et al. A tailored online screening decision aid for men with a family history of prostate cancer: Development, pilot-testing and evaluation. Asia Pac J Clin Oncol. 2011;7:109. PMID:.
399 Wayne EM. Who cares what surgeons think?. Effective clinical practice: ECP. Nov-Dec. 1999;2(6):299. [pmid: 10788030].
400 Welch HG. Informed choice in cancer screening. JAMA internal medicine. Dec. 9. 2013;173(22):2088. [pmid: 24145551].
401 Wells K, Jacobsen P, Meade C, et al., editors. Similarities and Differences in Informational Needs Among English vs. Spanish Speaking Cancer Patients Considering a Clinical Trial. Psycho-oncology. 2013. WILEY-BLACKWELL 111 RIVER ST, HOBOKEN 07030-5774, NJ USA.
402 Williamson C. Breast cancer: asking patients what they want. BMJ. Aug. 31. 1996;313(7056):506-7. [pmid: 8789964].
403 Wilson CJ, Flight IH, Zajac IT, et al. Protocol for population testing of an Internet-based Personalised Decision Support system for colorectal cancer screening. BMC medical informatics and decision making. 2010;10:50. [pmid: 20843369].
404 Wilson CJ, Zajac I, Flight IH, et al. Facilitating uptake of colorectal cancer screening: Does online tailored information help?. Asia Pac J Clin Oncol. 2012;8:134. PMID:.
405 Woolf SH, Krist A. Shared decision making for prostate cancer screening: do patients or clinicians have a choice?. Archives of internal medicine. Sep. 28. 2009;169(17):1557-9. [pmid: 19786673].
406 Wu RR, Himmel T, Buchanan A, et al., editors. IMPACT OF A FAMILY HISTORY COLLECTION TOOL, METREE (c), IN IDENTIFYING INDIVIDUALS AT HIGH-RISK FOR CANCER AND THROMBOSIS. Journal of general internal medicine. 2013. SPRINGER 233 SPRING ST, NEW YORK, NY 10013 USA.
407 Zikmund-Fisher BJ, Ubel PA, Smith DM, et al. Communicating side effect risks in a tamoxifen prophylaxis decision aid: the debiasing influence of pictographs. Patient education and counseling. Nov. 2008;73(2):209-14. [pmid: 18602242].
408 Therapeutic choices by children with cancer. The Journal of pediatrics. Jul. 1983;103(1):167-9. [pmid: 6864386].
409 Augestad KM, Norum J, Dehof S, et al. Cost-effectiveness and quality of life in surgeon versus general practitioner-organised colon cancer surveillance: a randomised controlled trial. BMJ open. 2013;3(4). [pmid: 23564936].
410 Barry MJ, Cherkin DC, YuChiao C, et al. A randomized trial of a multimedia shared decision-making program for men facing a treatment decision for benign prostatic hyperplasia. Disease Management and Clinical Outcomes. 1997;1(1):5-14. PMID:.
411 Brundage MD, Feldman-Stewart D, Dixon P, et al. A treatment trade-off based decision aid for patients with locally advanced non-small cell lung cancer. Health expectations: an international journal of public participation in health care and health policy. Mar. 2000;3(1):55-68. [pmid: 11281912].
412 Butow PN. Giving and using information: what we know and don't know. Patient education and counseling. Nov. 2009;77(2):149-50. [pmid: 19853789].
413 Feldman-Stewart D, Brundage MD, Van Manen L. A decision aid for men with early stage prostate cancer: theoretical basis and a test by surrogate patients. Health expectations: an international journal of public participation in health care and health policy. Dec. 2001;4(4):221-34. [pmid: 11703496].
414 Heller L, Parker PA, Youssef A, et al. Interactive digital education aid in breast reconstruction. Plastic and reconstructive surgery. Sep. 2008;122(3):717-24. [pmid: 18766034].
415 Juraskova I, Butow P, Bonner C, et al. Improving decision making about clinical trial participation - a randomised controlled trial of a decision aid for women considering participation in the IBIS-II breast cancer prevention trial. British journal of cancer. Jul. 8. 2014;111(1):1-7. [pmid: 24892447].
416 Kunkler IH, Prescott RJ, Lee RJ, et al. TELEMAM: a cluster randomised trial to assess the use of telemedicine in multi-disciplinary breast cancer decision making. Eur J Cancer. Nov. 2007;43(17):2506-14. [pmid: 17962011].
417 Lyon ME, Jacobs S, Briggs L, et al. Family-centered advance care planning for teens with cancer. JAMA pediatrics. May. 2013;167(5):460-7. [pmid: 23479062].
418 McBride CM, Bastian LA, Halabi S, et al. A tailored intervention to aid decision-making about hormone replacement therapy. American journal of public health. Jul. 2002;92(7):1112-4. [pmid: 12084693].
419 Murray E, Davis H, Tai SS, et al. Randomised controlled trial of an interactive multimedia decision aid on benign prostatic hypertrophy in primary care. BMJ. Sep. 1. 2001;323(7311):493-6. [pmid: 11532845].
420 Scandrett KG, Reitschuler-Cross EB, Nelson L, et al. Feasibility and effectiveness of the NEST13+ as a screening tool for advanced illness care needs. Journal of palliative medicine. Feb. 2010;13(2):161-9. [pmid: 19821699].
421 Schapira MM, Gilligan MA, McAuliffe T, et al. Decision-making at menopause: a randomized controlled trial of a computer-based hormone therapy decision-aid. Patient education and counseling. Jul. 2007;67(1-2):100-7. [pmid: 17400413].
422 Schwartz MD, Benkendorf J, Lerman C, et al. Impact of educational print materials on knowledge, attitudes, and interest in BRCA1/BRCA2: testing among Ashkenazi Jewish women. Cancer. Aug. 15. 2001;92(4):932-40. [pmid: 11550168].
423 Street RL Jr., Slee C, Kalauokalani DK, et al. Improving physician-patient communication about cancer pain with a tailored education-coaching intervention. Patient education and counseling. Jul. 2010;80(1):42-7. [pmid: 19962845].
424 Sundaresan P, Turner S, Kneebone A, et al. Evaluating the utility of a patient decision aid for potential participants of a prostate cancer trial (RAVES-TROG 08.03). Radiotherapy and oncology: journal of the European Society for Therapeutic Radiology and Oncology. Dec. 2011;101(3):521-4. [pmid: 21985948].
425 Vogel RI, Petzel SV, Cragg J, et al. Development and pilot of an advance care planning website for women with ovarian cancer: a randomized controlled trial. Gynecologic oncology. Nov. 2013;131(2):430-6. [pmid: 23988413].
426 Zeliadt SB, Hannon PA, Trivedi RB, et al. A preliminary exploration of the feasibility of offering men information about potential prostate cancer treatment options before they know their biopsy results. BMC medical informatics and decision making. 2013;13:19. [pmid: 23388205].
427 What suggestions could be made to help physicians deal with prostate screening issues with their patients in an office setting?. The Canadian journal of oncology. Nov. Suppl 1. 1994;4:127-31. [pmid: 8853505].
428 Ventura F, Sawatzky R, Ohlen J, et al. Evaluation of a web-based educational program for women diagnosed with breast cancer: why is the intervention effect absent?. Studies in health technology and informatics. 2013;192:1132. [pmid: 23920906].
429 Yoste E. Diagnosis cancer: beginning the journey. From the laboratory to the clinic. CURE: Cancer Updates, Research & Education. 2004;3(1):14. Language: English. Entry Date: 20041029. Publication Type: journal article.