# List of Included Studies

Key Question | References
1 | 1-83
2 | 82, 84-87

1 Albada A, van Dulmen S, Bensing JM, et al. Effects of a pre-visit educational website on information recall and needs fulfilment in breast cancer genetic counselling, a randomized controlled trial. Breast cancer research: BCR. 2012;14(2):R37. [pmid: 22394647].
2 Allen JD, Othus MK, Hart A Jr., et al. A randomized trial of a computer-tailored decision aid to improve prostate cancer screening decisions: results from the Take the Wheel trial. Cancer epidemiology, biomarkers & prevention: a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. Sep. 2010;19(9):2172-86. [pmid: 20716619].
3 Auvinen A, Hakama M, Ala-Opas M, et al. A randomized trial of choice of treatment in prostate cancer: the effect of intervention on the treatment chosen. BJU international. Jan. 2004;93(1):52-6. discussion 6. [pmid: 14678367].
4 Banegas MP, McClure JB, Barlow WE, et al. Results from a randomized trial of a web-based, tailored decision aid for women at high risk for breast cancer. Patient education and counseling. Jun. 2013;91(3):364-71. [pmid: 23395006].
5 Belkora JK, Hutton DW, Moore DH, et al. Does use of the adjuvant! model influence use of adjuvant therapy through better risk communication?. Journal of the National Comprehensive Cancer Network: JNCCN. Jul. 1. 2011;9(7):707-12. [pmid: 21715722].
6 Berry DL, Halpenny B, Hong F, et al. The Personal Patient Profile-Prostate decision support for men with localized prostate cancer: a multi-center randomized trial. Urologic oncology. Oct. 2013;31(7):1012-21. [pmid: 22153756].
7 Berry DL, Wang Q, Halpenny B, et al. Decision preparation, satisfaction and regret in a multi-center sample of men with newly diagnosed localized prostate cancer. Patient education and counseling. Aug. 2012;88(2):262-7. [pmid: 22608696].
8 Bosco JL, Halpenny B, Berry DL. Personal preferences and discordant prostate cancer treatment choice in an intervention trial of men newly diagnosed with localized prostate cancer. Health and quality of life outcomes. 2012;10:123. [pmid: 23021156].
9 Chan EC, McFall SL, Byrd TL, et al. A community-based intervention to promote informed decision making for prostate cancer screening among Hispanic American men changed knowledge and role preferences: a cluster RCT. Patient education and counseling. Aug. 2011;84(2):e44-51. [pmid: 21237611].
10 Davison BJ, Degner LF. Empowerment of men newly diagnosed with prostate cancer. Cancer nursing. Jun. 1997;20(3):187-96. [pmid: 9190093].
11 Davison BJ, Goldenberg SL, Wiens KP, et al. Comparing a generic and individualized information decision support intervention for men newly diagnosed with localized prostate cancer. Cancer nursing. Sep-Oct. 2007;30(5):E7-15. [pmid: 17876177].
12 Diefenbach MA, Mohamed NE, Butz BP, et al. Acceptability and preliminary feasibility of an internet/CD-ROM-based education and decision program for early-stage prostate cancer patients: randomized pilot study. Journal of medical Internet research. 2012;14(1):e6. [pmid: 22246148].
13 Dolan JG, Frisina S. Randomized controlled trial of a patient decision aid for colorectal cancer screening. Medical decision making: an international journal of the Society for Medical Decision Making. Mar-Apr. 2002;22(2):125-39. [pmid: 11958495].
14 Evans R, Joseph-Williams N, Edwards A, et al. Supporting informed decision making for prostate specific antigen (PSA) testing on the web: an online randomized controlled trial. Journal of medical Internet research. 2010;12(3):e27. [pmid: 20693148].
15 Fagerlin A, Dillard AJ, Smith DM, et al. Women's interest in taking tamoxifen and raloxifene for breast cancer prevention: response to a tailored decision aid. Breast cancer research and treatment. Jun. 2011;127(3):681-8. [pmid: 21442198].
16 Feldman-Stewart D, Tong C, Siemens R, et al. The impact of explicit values clarification exercises in a patient decision aid emerges after the decision is actually made: evidence from a randomized controlled trial. Medical decision making: an international journal of the Society for Medical Decision Making. Jul-Aug. 2012;32(4):616-26. [pmid: 22287534].
17 Frosch DL, Bhatnagar V, Tally S, et al. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Archives of internal medicine. Feb. 25. 2008;168(4):363-9. [pmid: 18299490].
18 Frosch DL, Kaplan RM, Felitti VJ. A randomized controlled trial comparing internet and video to facilitate patient education for men considering the prostate specific antigen test. Journal of general internal medicine. Oct. 2003;18(10):781-7. [pmid: 14521639].
19 Gattellari M, Ward JE. Does evidence-based information about screening for prostate cancer enhance consumer decision-making? A randomised controlled trial. Journal of medical screening. 2003;10(1):27-39. [pmid: 12790313].
20 Gattellari M, Ward JE. A community-based randomised controlled trial of three different educational resources for men about prostate cancer screening. Patient education and counseling. May. 2005;57(2):168-82. [pmid: 15911190].
21 Goel V, Sawka CA, Thiel EC, et al. Randomized trial of a patient decision aid for choice of surgical treatment for breast cancer. Medical decision making: an international journal of the Society for Medical Decision Making. Jan-Feb. 2001;21(1):1-6. [pmid: 11206942].
22 Green MJ, Biesecker BB, McInerney AM, et al. An interactive computer program can effectively educate patients about genetic testing for breast cancer susceptibility. American journal of medical genetics. Sep. 15. 2001;103(1):16-23. [pmid: 11562929].
23 Green MJ, Peterson SK, Baker MW, et al. Use of an educational computer program before genetic counseling for breast cancer susceptibility: effects on duration and content of counseling sessions. Genetics in medicine: official journal of the American College of Medical Genetics. Apr. 2005;7(4):221-9. [pmid: 15834239].
24 Green MJ, Peterson SK, Baker MW, et al. Effect of a computer-based decision aid on knowledge, perceptions, and intentions about genetic testing for breast cancer susceptibility: a randomized controlled trial. JAMA: the journal of the American Medical Association. Jul. 28. 2004;292(4):442-52. [pmid: 15280342].
25 Griffith JM, Lewis CL, Brenner AR, et al. The effect of offering different numbers of colorectal cancer screening test options in a decision aid: a pilot randomized trial. BMC medical informatics and decision making. 2008;8:4. [pmid: 18218084].
26 Hacking B, Wallace L, Scott S, et al. Testing the feasibility, acceptability and effectiveness of a ‘decision navigation’ intervention for early stage prostate cancer patients in Scotland--a randomised controlled trial. Psycho-oncology. May. 2013;22(5):1017-24. [pmid: 22570252].
27 Hall MJ, Manne SL, Winkel G, et al. Effects of a decision support intervention on decisional conflict associated with microsatellite instability testing. Cancer epidemiology, biomarkers & prevention: a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. Feb. 2011;20(2):249-54. [pmid: 21212064].
28 Holt CL, Wynn TA, Litaker MS, et al. A comparison of a spiritually based and non-spiritually based educational intervention for informed decision making for prostate cancer screening among church-attending African-American men. Urologic nursing. Jul-Aug. 2009;29(4):249-58. [pmid: 19718941].
29 Hooker GW, Leventhal KG, DeMarco T, et al. Longitudinal changes in patient distress following interactive decision aid use among BRCA1/2 carriers: a randomized trial. Medical decision making: an international journal of the Society for Medical Decision Making. May-Jun. 2011;31(3):412-21. [pmid: 20876346].
30 Ilic D, Egberts K, McKenzie JE, et al. Informing men about prostate cancer screening: a randomized controlled trial of patient education materials. Journal of general internal medicine. Apr. 2008;23(4):466-71. [pmid: 18373146].
31 Jibaja-Weiss ML, Volk RJ, Granchi TS, et al. Entertainment education for breast cancer surgery decisions: a randomized trial among patients with low health literacy. Patient education and counseling. Jul. 2011;84(1):41-8. [pmid: 20609546].
32 Korfage IJ, Fuhrel-Forbis A, Ubel PA, et al. Informed choice about breast cancer prevention: randomized controlled trial of an online decision aid intervention. Breast cancer research: BCR. Sep. 3. 2013;15(5):R74. [pmid: 24004815].
33 Lam WW, Chan M, Or A, et al. Reducing treatment decision conflict difficulties in breast cancer surgery: a randomized controlled trial. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Aug. 10. 2013;31(23):2879-85. [pmid: 23835709].
34 Lepore SJ, Wolf RL, Basch CE, et al. Informed decision making about prostate cancer testing in predominantly immigrant black men: a randomized controlled trial. Annals of behavioral medicine: a publication of the Society of Behavioral Medicine. Dec. 2012;44(3):320-30. [pmid: 22825933].
35 Lerman C, Biesecker B, Benkendorf JL, et al. Controlled trial of pretest education approaches to enhance informed decision-making for BRCA1 gene testing. Journal of the National Cancer Institute. Jan. 15. 1997;89(2):148-57. [pmid: 8998184].
36 Manne SL, Meropol NJ, Weinberg DS, et al. Facilitating informed decisions regarding microsatellite instability testing among high-risk individuals diagnosed with colorectal cancer. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Mar. 10. 2010;28(8):1366-72. [pmid: 20142594].
37 Maslin Anna M, Michael B, Secker WJ, et al. Shared decision-making using an interactive video disk system for women with early breast cancer. 1998. PMID:.
38 Mathieu E, Barratt A, Davey HM, et al. Informed choice in mammography screening: a randomized trial of a decision aid for 70-year-old women. Archives of internal medicine. Oct. 22. 2007;167(19):2039-46. [pmid: 17954796].
39 Mathieu E, Barratt AL, McGeechan K, et al. Helping women make choices about mammography screening: an online randomized trial of a decision aid for 40-year-old women. Patient education and counseling. Oct. 2010;81(1):63-72. [pmid: 20149953].
40 McCaffery KJ, Irwig L, Turner R, et al. Psychosocial outcomes of three triage methods for the management of borderline abnormal cervical smears: an open randomised trial. BMJ. 2010;340:b4491. [pmid: 20179125].
41 McCaffery KJ, Turner R, Macaskill P, et al. Determining the impact of informed choice: separating treatment effects from the effects of choice and selection in randomized trials. Medical decision making: an international journal of the Society for Medical Decision Making. Mar-Apr. 2011;31(2):229-36. [pmid: 21041538].
42 Miller DP Jr., Spangler JG, Case LD, et al. Effectiveness of a web-based colorectal cancer screening patient decision aid: a randomized controlled trial in a mixed-literacy population. American journal of preventive medicine. Jun. 2011;40(6):608-15. [pmid: 21565651].
43 Miller SM, Fleisher L, Roussi P, et al. Facilitating informed decision making about breast cancer risk and genetic counseling among women calling the NCI's Cancer Information Service. Journal of health communication. Suppl 1. 2005;10:119-36. [pmid: 16377604].
44 Mishel MH, Germino BB, Lin L, et al. Managing uncertainty about treatment decision making in early stage prostate cancer: a randomized clinical trial. Patient education and counseling. Dec. 2009;77(3):349-59. [pmid: 19819096].
45 Myers RE, Daskalakis C, Cocroft J, et al. Preparing African-American men in community primary care practices to decide whether or not to have prostate cancer screening. Journal of the National Medical Association. Aug. 2005;97(8):1143-54. [pmid: 16173330].
46 Myers RE, Daskalakis C, Kunkel EJ, et al. Mediated decision support in prostate cancer screening: a randomized controlled trial of decision counseling. Patient education and counseling. May. 2011;83(2):240-6. [pmid: 20619576].
47 Ozanne EM, Annis C, Adduci K, et al. Pilot trial of a computerized decision aid for breast cancer prevention. The breast journal. Mar-Apr. 2007;13(2):147-54. [pmid: 17319855].
48 Partin MR, Nelson D, Flood AB, et al. Who uses decision aids? Subgroup analyses from a randomized controlled effectiveness trial of two prostate cancer screening decision support interventions. Health expectations: an international journal of public participation in health care and health policy. Sep. 2006;9(3):285-95. [pmid: 16911143].
49 Partin MR, Nelson D, Radosevich D, et al. Randomized trial examining the effect of two prostate cancer screening educational interventions on patient knowledge, preferences, and behaviors. Journal of general internal medicine. Aug. 2004;19(8):835-42. [pmid: 15242468].
50 Peele PB, Siminoff LA, Xu Y, et al. Decreased use of adjuvant breast cancer therapy in a randomized controlled trial of a decision aid with individualized risk information. Medical decision making: an international journal of the Society for Medical Decision Making. May-Jun. 2005;25(3):301-7. [pmid: 15951457].
51 Pignone M, Harris R, Kinsinger L. Videotape-based decision aid for colon cancer screening. A randomized, controlled trial. Annals of internal medicine. Nov. 21. 2000;133(10):761-9. [pmid: 11085838].
52 Rubel SK, Miller JW, Stephens RL, et al. Testing the effects of a decision aid for prostate cancer screening. Journal of health communication. Apr. 2010;15(3):307-21. [pmid: 20432110].
53 Ruffin MTt, Fetters MD, Jimbo M. Preference-based electronic decision aid to promote colorectal cancer screening: results of a randomized controlled trial. Preventive medicine. Oct. 2007;45(4):267-73. [pmid: 17689600].
54 Salkeld G, Cunich M, Dowie J, et al. 1249 THE ROLE OF PERSONALIZED CHOICE: A RANDOMIZED CONTROLLED TRIAL OF AN ONLINE DECISION AID FOR PROSTATE CANCER SCREENING. The Journal of Urology. 2013;189(4):e511. PMID:.
55 Sawka AM, Straus S, Rotstein L, et al. Randomized controlled trial of a computerized decision aid on adjuvant radioactive iodine treatment for patients with early-stage papillary thyroid cancer. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Aug. 10. 2012;30(23):2906-11. [pmid: 22753906].
56 Schroy PC 3rd, Emmons K, Peters E, et al. The impact of a novel computer-based decision aid on shared decision making for colorectal cancer screening: a randomized trial. Medical decision making: an international journal of the Society for Medical Decision Making. Jan-Feb. 2011;31(1):93-107. [pmid: 20484090].
57 Schroy PC 3rd, Emmons KM, Peters E, et al. Aid-assisted decision making and colorectal cancer screening: a randomized controlled trial. American journal of preventive medicine. Dec. 2012;43(6):573-83. [pmid: 23159252].
58 Schwartz MD, Valdimarsdottir HB, DeMarco TA, et al. Randomized trial of a decision aid for BRCA1/BRCA2 mutation carriers: impact on measures of decision making and satisfaction. Health psychology: official journal of the Division of Health Psychology, American Psychological Association. Jan. 2009;28(1):11-9. [pmid: 19210013].
59 Sheridan SL, Golin C, Bunton A, et al. Shared decision making for prostate cancer screening: the results of a combined analysis of two practice-based randomized controlled trials. BMC medical informatics and decision making. 2012;12:130. [pmid: 23148458].
60 Siminoff LA, Gordon NH, Silverman P, et al. A decision aid to assist in adjuvant therapy choices for breast cancer. Psycho-oncology. Nov. 2006;15(11):1001-13. [pmid: 16511899].
61 Smith SK, Simpson JM, Trevena LJ, McCaffery KJ. Factors Associated with Informed Decisions and Participation in Bowel Cancer Screening among Adults with Lower Education and Literacy. Medical decision making: an international journal of the Society for Medical Decision Making. 2014. Jan. 13. [pmid: 24421292].
62 Smith SK, Trevena L, Simpson JM, et al. A decision aid to support informed choices about bowel cancer screening among adults with low education: randomised controlled trial. BMJ. 2010;341:c5370. [pmid: 20978060].
63 Stephens RL, Xu Y, Volk RJ, et al. Influence of a patient decision aid on decisional conflict related to PSA testing: a structural equation model. Health psychology: official journal of the Division of Health Psychology, American Psychological Association. Nov. 2008;27(6):711-21. [pmid: 19025266].
64 Street RL Jr., Voigt B, Geyer C Jr., et al. Increasing patient involvement in choosing treatment for early breast cancer. Cancer. Dec. 1. 1995;76(11):2275-85. [pmid: 8635032].
65 Taylor KL, Williams RM, Davis K, et al. Decision Making in Prostate Cancer Screening Using Decision Aids vs Usual Care: A Randomized Clinical Trial. JAMA internal medicine. 2013. Jul. 29. [pmid: 23896732].
66 Tiller K, Meiser B, Gaff C, et al. A randomized controlled trial of a decision aid for women at increased risk of ovarian cancer. Medical decision making: an international journal of the Society for Medical Decision Making. Jul-Aug. 2006;26(4):360-72. [pmid: 16855125].
67 Trevena LJ, Irwig L, Barratt A. Randomized trial of a self-administered decision aid for colorectal cancer screening. Journal of medical screening. 2008;15(2):76-82. [pmid: 18573775].
68 van Roosmalen MS, Stalmeier PF, Verhoef LC, et al. Randomized trial of a shared decision-making intervention consisting of trade-offs and individualized treatment information for BRCA1/2 mutation carriers. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. Aug. 15. 2004;22(16):3293-301. [pmid: 15310772].
69 van Tol-Geerdink JJ, Willem Leer J, Weijerman PC, et al. Choice between prostatectomy and radiotherapy when men are eligible for both: a randomized controlled trial of usual care vs decision aid. BJU international. Apr. 2013;111(4):564-73. [pmid: 22882966].
70 Vodermaier A, Caspari C, Koehm J, et al. Contextual factors in shared decision making: a randomised controlled trial in women with a strong suspicion of breast cancer. British journal of cancer. Feb. 24. 2009;100(4):590-7. [pmid: 19209172].
71 Vodermaier A, Caspari C, Wang L, et al. How and for whom are decision aids effective? Long-term psychological outcome of a randomized controlled trial in women with newly diagnosed breast cancer. Health psychology: official journal of the Division of Health Psychology, American Psychological Association. Jan. 2011;30(1):12-9. [pmid: 21299290].
72 Volk RJ, Cass AR, Spann SJ. A randomized controlled trial of shared decision making for prostate cancer screening. Archives of family medicine. Jul-Aug. 1999;8(4):333-40. [pmid: 10418541].
73 Volk RJ, Jibaja-Weiss ML, Hawley ST, et al. Entertainment education for prostate cancer screening: a randomized trial among primary care patients with low health literacy. Patient education and counseling. Dec. 2008;73(3):482-9. [pmid: 18760888].
74 Volk RJ, Spann SJ, Cass AR, et al. Patient education for informed decision making about prostate cancer screening: a randomized controlled trial with 1-year follow-up. Annals of family medicine. May-Jun. 2003;1(1):22-8. [pmid: 15043176].
75 Wakefield CE, Meiser B, Homewood J, et al. A randomized controlled trial of a decision aid for women considering genetic testing for breast and ovarian cancer risk. Breast cancer research and treatment. Jan. 2008;107(2):289-301. [pmid: 17333332].
76 Wakefield CE, Meiser B, Homewood J, et al. A randomized trial of a breast/ovarian cancer genetic testing decision aid used as a communication aid during genetic counseling. Psycho-oncology. Aug. 2008;17(8):844-54. [pmid: 18613319].
77 Wakefield CE, Meiser B, Homewood J, et al. Randomized trial of a decision aid for individuals considering genetic testing for hereditary nonpolyposis colorectal cancer risk. Cancer. Sep. 1. 2008;113(5):956-65. [pmid: 18618513].
78 Watson E, Hewitson P, Brett J, et al. Informed decision making and prostate specific antigen (PSA) testing for prostate cancer: a randomised controlled trial exploring the impact of a brief patient decision aid on men's knowledge, attitudes and intention to be tested. Patient education and counseling. Nov. 2006;63(3):367-79. [pmid: 16875796].
79 Watts KJ, Meiser B, Wakefield CE, et al. Online Prostate Cancer Screening Decision Aid for At-Risk Men: A Randomized Trial. Health psychology: official journal of the Division of Health Psychology, American Psychological Association. 2013. Nov. 25. [pmid: 24274808].
80 Whelan T, Levine M, Willan A, et al. Effect of a decision aid on knowledge and treatment decision making for breast cancer surgery: a randomized trial. JAMA: the journal of the American Medical Association. Jul. 28. 2004;292(4):435-41. [pmid: 15280341].
81 Whelan T, Sawka C, Levine M, et al. Helping patients make informed choices: a randomized trial of a decision aid for adjuvant chemotherapy in lymph node-negative breast cancer. Journal of the National Cancer Institute. Apr. 16. 2003;95(8):581-7. [pmid: 12697850].
82 Wilkes MS, Day FC, Srinivasan M, et al. Pairing physician education with patient activation to improve shared decisions in prostate cancer screening: a cluster randomized controlled trial. Annals of family medicine. Jul-Aug. 2013;11(4):324-34. [pmid: 23835818].
83 Williams RM, Davis KM, Luta G, et al. Fostering informed decisions: a randomized controlled trial assessing the impact of a decision aid among men registered to undergo mass screening for prostate cancer. Patient education and counseling. Jun. 2013;91(3):329-36. [pmid: 23357414].
84 Bryan T, Snyder E, Estrada C, et al., editors. Education in Delivering Patient-Centered Care: Provider Comfort Level in Counseling Women Ages 40-49 Regarding Breast Cancer Screening Options. Journal of Investigative Medicine. 2013.
85 Feng B, Srinivasan M, Hoffman JR, et al. Physician communication regarding prostate cancer screening: analysis of unannounced standardized patient visits. Annals of family medicine. Jul-Aug. 2013;11(4):315-23. [pmid: 23835817].
86 Gattellari M, Donnelly N, Taylor N, et al. Does ‘peer coaching’ increase GP capacity to promote informed decision making about PSA screening? A cluster randomised trial. Family practice. Jun. 2005;22(3):253-65. [pmid: 15824055].
87 Uy V, May Suepattra G, Tietbohl Caroline, Frosch Dominick L. Barriers and facilitators to routine distribution of patient decision support interventions: a preliminary study in community-based primary care settings. Health Expectations. 2014;17(3):353-64. Language: English. Entry Date: 20140509. Revision Date: 20140516. Publication Type: journal article. [pmid: 22212453].