# Table of Study Characteristics

Table D1 Characteristics of included studies

Table 1B Key Question 2