# Description of Discrepancies With the 2014 Cochrane Systematic Review

The most recent update of the Cochrane Systematic Review is searched the literature through June 2012, and included 115 trials in all healthcare conditions. Of these, 47 are in people facing decisions related to screening, diagnosis, or treatment of no worse than early cancer.

Considering cancer and non-cancer conditions, the authors of the Cochrane Review concluded that there is high-quality evidence that decision aids compared to usual care improve people's knowledge regarding options, and reduce their decisional conflict related to feeling uninformed and unclear about their personal values; that there is moderate-quality evidence that decision aids compared to usual care stimulate people to take a more active role in decision making, and improve accurate risk perceptions when probabilities are included in decision aids, compared to not being included; and that there is low-quality evidence that decision aids improve congruence between the chosen option and the patient's values.

Regarding randomized evidence, the Cochrane systematic review and the current work have included mostly overlapping sets of studies. Of the 115 trials in the Cochrane review, 47 are in patients facing screening, diagnostic or treatment decisions in early cancer. We have included 67 trials. Overall:

- 41 trials are included in both the Cochrane review and this work,
- 6 trials are included in the Cochrane review but are excluded from our work, because the intervention was not judged to be a decision aid, using our operationalization of the inclusion criteria (e.g., we did not find a description that the intervention included even implicit elicitation of values), and
- 26 trials are included in our work but not in the Cochrane review. Of these, 10 were published after the last search of the Cochrane review (June 2012), 14 were in the excluded studies list, and 2 were not mentioned in the included/excluded lists of the Cochrane review.

We verified our decisions for the 32 trials in which our decisions for eligibility were at odds with those of the Cochrane reviewers. We concluded that the most plausible explanation for the disagreements is in the operationalization of the eligibility criteria.

## Sensitivity Analysis

The conclusions in our main report would remain qualitatively the same if we were to consider only the 41 trials included in the Cochrane review. Indicatively, we list the main results for the three meta-analyses including only the subset of our studies that were included in the Cochrane report.

### Knowledge About the Condition or the Available Options

In total, 23 trials (7736 participants) would be included in the main analysis. Overall, using decision aids resulted in higher knowledge scores (standardized mean difference or SMD = 0.19, 95% credible interval [CrI]: 0.09, 0.29) compared to not using them. (An SMD of 0.20-0.30 can be considered a moderate effect.) The effect was 0.25, 95% CrI: 0.11, 0.38) among people at average risk of cancer, 0.22 (95% CrI: 0.03, 0.39) among those at high risk, and 0.05 (95% CrI: -0.19, 0.29) among patients with early cancer. However, the observed effects were not different beyond what can be explained by chance. There was no evidence for effect modification by the delivery format or content of the DA or other attributes, or by methodological characteristics of the studies. There were indications for relatively large between-study heterogeneity.

### Decisional Conflict

In total, 18 trials (4176 participants) would be included in the main analysis. Overall, using decision aids resulted in lower decisional conflict scores (weighted mean difference = -0.10, 95% credible interval [CrI]: -0.19, -0.01) compared to not using them. The effect was -0.16, 95% CrI: -0.32, 0.01) among people at average risk of cancer, -0.12 (95% CrI: -0.31, 0.04) among those at high risk, and -0.03 (95% CrI: -0.18, 0.13) among patients with early cancer. The observed effects were not statistically significantly different (their differences could be explained by chance alone). The observed effects were not different beyond what can be explained by chance. There was no evidence for effect modification by the delivery format or content of the DA or other attributes, or by methodological characteristics of the studies. There were indications for relatively large between-study heterogeneity.

### Anxiety

In total, 8 trials (1959 participants) would be included in the main analysis. Overall, using decision aids resulted in higher anxiety, as measured by the state anxiety scale of the State-Trait Anxiety Inventory (weighted mean difference = 0.16, 95% credible interval [CrI]: -1.43, 1.29) compared to not using them. There were indications for relatively large between-study heterogeneity. Because there were fewer than 10 studies, we did not run meta-regression analyses by the delivery format or content of the DA or other attributes, or by methodological characteristics of the studies. There were indications for relatively large between-study heterogeneity (see Methods section).