# Meta-Analysis Model

Analysis model: Hierarchical random effects meta-regression model

We assumed a normal distribution at the between and within-study levels:

y_ij_ ~ N ( d_ij_ , σ_ij_^2^ )

where y_ij_ and σ_ij_^2^ are the observed study-level mean response and sampling variance in study i and arm j; d_ij_ is the unobserved true mean response.

We used a linear form on d_ij_ to account for decision aid effects and their modification by predictors. For example for a single predictor write

d_ij_ = β_0 , i_ + β_1 , i_ x_DA , ij_ + β_2 , i_ x_pred , ij_ + γ_i_ x_DA , ij_ x_pred , ij_

where the x variables are binary indicators of whether a condition is fulfilled and pred stands for predictor. x_DA_ records the presence of a DA and x_pred_ indicates whether a study accounts for the predictors of interest listed in Tables 2, 3 and 4 in the main text. We repeated the meta-regression individually for each predictor of interest. We also added terms for population group (high risk population, cancer population) and examined interactions between populations and predictors. To obtain SMDs, we scaled y_ij_ and σ_ij_^2^ with the pooled standard deviation in study i.

We used a Bayesian framework for the meta-analysis and assigned the following priors to model coefficients:

- β_0,i_ ∼ N(0, 0.01)
- β_1 , i_ ~ N ( B_1 , i_ , τ_B_1 , i__^2^ )
- β_1,i_ ∼ N(0, 0.01) (for SMDs on knowledge), β_1,i_ ∼ N(0, 0.0001) (for WMDs on decisional conflict and anxiety)
- τ_B_1 , i__ ~ U ( 0.001 , 2 ) (for the SMD model on knowledge), τ_B_1 , i__ ~ U ( 0.001 , 20 ) (for WMDs on decisional conflict and anxiety)
- β_2,i_ ∼ N(0, 0.01)
- γ_i_ ~ N ( Γ_i_ , θ_Γ_i__^2^ )
- Γ_i_ ∼ N(0, 0.01) (for SMDs on knowledge), Γ_i_ ∼ N(0, 0.0001) (for WMDs on decisional conflict and anxiety)
- θ_Γi_ ∼ U(0.001, 2) (for the SMD model on knowledge), θ_Γi_ ∼ U(0.001, 20) (for WMDs on decisional conflict and anxiety)

In sensitivity analyses we increased the variance in the prior distributions (results summarized in the text but not shown in detail).