# Search Strategies

KQ1: Adapted from the strategy used in Decision aids for people facing health treatment or screening decisions. Stacey D, Bennett CL, Barry MJ, Col NF, Eden KB, Holmes-Rovner M, Llewellyn-Thomas H, Lyddiatt A, Légaré F, Thomson R. Cochrane Database Syst Rev. Oct. 5. 2011;(10). with the addition of cancer and some publication types.

## PubMed/ MEDLINE^®^ (dates run 10/2/2013 and 6/5/2014; citations retrieved: 7585)

(“Neoplasms”[Mesh] OR cancer OR cancers OR neoplasm* OR malignan* OR premalignan* OR precancerous) AND (((choice behavior[MeSH:noexp] OR decision making[MeSH:noexp] OR decision support techniques[MeSH] OR educational technology [MeSH:noexp] OR (decision[tw] OR decisions[tw]) OR (choic*[tw] OR preference*[tw]) OR communication package[tw]) AND (health education[MeSH] OR Health Knowledge, Attitudes, Practice [MeSH:noexp] OR informed consent[tw] OR patient[tw] OR consumer[tw])) OR ((consumer* OR parent OR parents OR woman OR women OR man OR men OR personal OR interpersonal OR patient OR patients OR consumer OR personal OR individual OR nurse OR physician* OR clinician OR doctor OR “general practitioner” Or “gp”) AND (participat* OR decision OR choice* OR preference)) OR “Decision Theory”[Mesh] OR “Decision Support Systems, Clinical”[Mesh] OR “Decision Making, Computer-Assisted”[Mesh] OR “shared decision” OR ((“professional-patient” OR “provider-patient”) AND (relation* OR communication)) OR ((“health care” OR healthcare) AND (providers OR professional)) OR “informed decision” OR “informed choice” OR “decision support” OR choice OR ((patient or consumer) AND involvement)) AND (clinical trial[pt] OR randomized controlled trial[pt] OR random*[tw] OR (double[tw] AND blind*[tw]) OR double-blind method [MeSH:noexp]) limit 2008-

## EMBASE^®^ (run 10/17/13 and 6/5/2014; citations retrieved: 1368)

- #11 AND #17 AND ([controlled clinical trial]/lim OR [randomized controlled trial]/lim) AND [humans]/lim AND [embase]/lim AND [2009-2014]/py
- #17: ‘choice behavior’:ti OR ’choice behavior’:ab OR ’decision making’:ti OR ’decision making’:ab OR ’decision support techniques’:ti OR ’decision support techniques’:ab OR ’educational technology’:ti OR’educational technology’:ab OR ’communication package’:ti OR ’communication package’:ab OR ’health education’:ti OR ’health education’:ab OR ’health knowledge’:ti OR ’health knowledge’:ab OR ’health attitudes’:ti OR ’health attitudes’:ab OR ’health practice’:ti OR ’health practice’:ab OR (‘patient’/exp OR patient OR ’consumer’/exp OR consumer* OR ’parent’/exp OR parent OR ’parents’/exp OR parents OR’woman’/exp OR woman OR ’women’/exp OR women OR ’man’/exp OR man OR ’men’/exp OR men OR interpersonal OR personal OR individual OR ’nurse’/exp OR nurse OR physician* OR clinician OR’doctor’/exp OR doctor OR ’general practitioner’/exp OR ’general practitioner’ OR ’gp’ AND (decision:ti OR decision:ab OR choice:ti OR choice:ab OR preference:ti OR preference:ab OR participation:ti ORparticipation:ab)) OR ’decision theory’/exp OR ’decision theory’:ti OR ’decision theory’:ab OR ’decision support systems, clinical’/exp OR ’decision making, computer-assisted’/exp OR ’shared decision’:ti OR’shared decision’:ab OR ’informed decision’:ti OR ’informed decision’:ab OR ’informed choice’:ti OR ’informed choice’:ab OR ’decision support’/exp OR ’decision support’:ti OR ’decision support’:ab OR (‘patient’/exp OR patient OR ’consumer’/exp OR consumer AND involvement)
- #11: #9 AND #10
- #10: clinical AND trial OR randomized AND controlled AND trial OR random* OR (double AND blind*) OR ’double blind’ AND (‘method’ OR ’method’/exp OR method)
- #9: ‘neoplasms’/exp OR neoplasms OR ’cancer’/exp OR cancer OR ’cancers’/exp OR cancers OR neoplasm* OR malignan* OR premalignan* OR precancerous

## Cochrane Central Register of Controlled Trials (run 10/2/13 and 6/5/2014; citations retrieved: 1591)

(Neoplasm* OR cancer OR cancers OR neoplasm* OR malignan* OR premalignan* OR precancerous) and (((choice behavior OR decision making OR decision support techniques OR educational technology OR (decision OR decisions) OR (choic* OR preference*) OR communication package) AND (health education OR Health Knowledge, Attitudes, Practice OR informed consent OR patient OR consumer)) OR ((consumer* OR parent OR parents OR woman OR women OR man OR men OR personal OR interpersonal OR patient OR patients OR consumer OR personal OR individual OR nurse OR physician* OR clinician OR doctor OR “general practitioner” OR “gp”) AND (participat* OR decision OR choice* OR preference)) OR “Decision Theory” OR “Decision Support Systems, Clinical” OR “Decision Making, Computer-Assisted” OR “shared decision” OR ((“professional-patient” OR “provider-patient”) AND (relation* OR communication)) OR ((“health care” OR healthcare) AND (provider OR professional)) OR “informed decision” OR “informed choice” OR “decision support” OR choice OR ((patient or consumer) AND involvement)) AND (clinical trial OR randomized controlled trial OR random* OR (double AND blind*) OR double-blind method) from 2008, in Cochrane Reviews (Reviews and Protocols), Other Reviews, Trials, Methods Studies, Technology Assessments, Economic Evaluations (Word variations have been searched)

## Cumulative Index to Nursing and Allied Health Literature (CINAHL^®^) and PsycINFO (run 10/2/13, 10/17/13 and 6/5/2014; citations retrieved: CINAHL 775; PsycINFO 319)

S11 S2 AND S4 AND S10 Limiters – Published date 20090101-
S10 ((MH “Clinical Trials”) OR (MH “Randomized Controlled Trials”) OR “clinical trial”) OR ( clinical trial OR randomized controlled trial OR random* OR (double AND blind*) OR double-blind method ) or (MH “Double-Blind Studies”)
S4 ( (MH “Decision Support Systems, Clinical”) OR (MH “Decision Support Systems, Management”) OR (MH “Decision Support Techniques”) OR (MH “Decision-Making Support (Iowa NIC)”) OR “decision support” ) OR ( (((choice behavior OR decision making OR decision support techniques OR educational technology OR (decision OR decisions) OR (choic* OR preference*) OR communication package) AND (health education OR Health Knowledge, Attitudes, Practice OR informed consent OR patient OR consumer)) OR ((consumer* OR parent OR parents OR woman OR women OR man OR men OR personal OR interpersonal OR patient OR patients OR consumer OR personal OR individual OR nurse OR physician* OR clinician OR doctor OR “general practitioner” OR “gp”) AND (participat* OR decision OR choice* OR preference)) OR “Decision Theory” OR “Decision Support Systems, Clinical” OR “Decision Making, Computer-Assisted” OR “shared decision” OR ((“professional-patient” OR “provider-patient”) AND (relation* OR communication)) OR ((“health care” OR healthcare) AND (provider OR professional)) OR “informed decision” OR “informed choice” OR “decision support” OR choice OR ((patient or consumer) AND involvement)) )
S2 (MH “Neoplasms+”) or cancer OR cancers OR neoplasm* OR malignan* OR premalignan* OR precancerous

KQ2: adapted from Interventions for improving the adoption of shared decision making by healthcare professionals. Légaré F, Ratté S, Stacey D, Kryworuchko J, Gravel K, Graham ID, Turcotte S. Cochrane Database Syst Rev. May. 12. 2010;(5). with the addition of cancer terms from KQ1 and the EPOC strategy for limiting publication types.

## PubMed/ MEDLINE^®^ (date run 10/17/2013 and 6/5/2014; citations retrieved: 2200)

Search (((((((shared decision*[tiab] or sharing decision*[tiab] or informed decision*[tiab] or informed choice*[tiab] or decision aid*[tiab] or ((share*[ti] or sharing*[ti] or informed*[ti]) and (decision*[ti] or deciding*[ti] or choice*[ti])))) OR (((decision making[mh:noexp] or decision support techniques[mh:noexp] or decision support systems, clinical[mh] or choice behaviour[mh:noexp] or decision making*[tiab] or decision support*[tiab] or choice behaviour*[tiab] or ((decision*[ti] or choice*[ti]) and (making*[ti] or support*[ti] or behaviour*[ti])))) AND (patient participation[mh] or patient participation*[tiab] or consumer participation*[tiab] or patient involvement*[tiab] or consumer involvement*[tiab] or “training intervention”[tw] or ((patient[ti] or patients[ti] or consumer*[ti]) and (involvement*[ti] or involving*[ti] or participation*[ti] or participating*[ti]))))) OR (((decision making[mh:noexp] or decision support techniques[mh:noexp] or decision support systems, clinical[mh] or choice behaviour[mh:noexp] or decision making*[tiab] or decision support*[tiab] or choice behaviour*[tiab] or ((decision*[ti] or choice*[ti]) and (making*[ti] or support*[ti] or behaviour*[ti])))) AND (professional-patient relations[mh] or ((nurses[mh] or physicians[mh] or nurse*[ti] or physician*[ti] or clinician*[ti] or doctor*[ti] or general practitioner*[ti] or gps[ti] or health care professional*[ti] or healthcare professional*[ti] or health care provider*[ti] or healthcare provider*[ti] or resident*[ti]) and (patients[mh] or patient[ti] or consumer*[ti] or people*[ti]))))) OR (((patient participation[mh] or patient participation*[tiab] or consumer participation*[tiab] or patient involvement*[tiab] or consumer involvement*[tiab] or “training intervention”[tw] or ((patient[ti] or patients[ti] or consumer*[ti]) and (involvement*[ti] or involving*[ti] or participation*[ti] or participating*[ti])))) AND (professional-patient relations[mh] or ((nurses[mh] or physicians[mh] or nurse*[ti] or physician*[ti] or clinician*[ti] or doctor*[ti] or general practitioner*[ti] or gps[ti] or health care professional*[ti] or healthcare professional*[ti] or health care provider*[ti] or healthcare provider*[ti] or resident*[ti]) and (patients[mh] or patient[ti] or consumer*[ti] or people*[ti])))))) AND ((((((((((((((((((((((intervention*[tw] or (intervention*[tw] and (clinician*[tw] or collaborat*[tw] or community[tw] or complex[tw] or DESIGN*[tw] or doctor*[tw] or educational[tw] or family doctor*[tw] or family physician*[tw] or family practitioner*[tw] or financial[tw] or GP or general practice*[tw] or hospital[tw] or hospitals[tw] or impact*[tw] or improv*[tw] or individualize*[tw] or individualizing[tw] or interdisciplin*[tw] or multicomponent or multi-component or multidisciplin*[tw] or multi-disciplin*[tw] or multifacet*[tw] or multi-facet*[tw] or multimodal*[tw] or multi-modal*[tw] or personalize*[tw] or personalizing or pharmacies or pharmacist* or pharmacy or physician* or practitioner* or prescrib* or prescription*[tw] or primary care[tw] or professional*[tw] or provider*[tw] or regulatory[tw] or regulatory[tw] or tailor*[tw] or target*[tw] or team*[tw] or usual care[tw])))) OR ((pre-intervention*[tw] or preintervention*[tw] or “pre intervention*”[tw] or post-intervention*[tw] or postintervention*[tw] or “post intervention*”[tw]))) OR ((hospital or patient) and (study or studies or care or health or practitioner* or provider* or physician* or nurse* or nursing or doctor))) OR demonstration project*[tw]) OR ((pre-post[tw] or “pre test*”[tw] or pretest*[tw] or posttest*[tw] or “post test*”[tw] or (pre[tw] and post[tw])))) OR ((pre-workshop[tw] or post-workshop[tw] or (before[tw] and workshop[tw]) or (after[tw] and workshop[tw])))) OR (trial[tw] or ((study[tw] and aim*[tw]) or “our study”[tw]))) OR ((before[tw] and (after[tw] or during[tw])))) OR ((“quasi-experiment*” or quasiexperiment* or “quasi random*” or quasirandom* or “quasi control*” or quasicontrol* or ((quasi or experimental) and (method or study or trial or design*))))) OR ((“time series” and interrupt*))) OR ((time points[tw] and (over[tw] or multiple[tw] or three[tw] or four[tw] or five[tw] or six[tw] or seven[tw] or eight[tw] or nine[tw] or ten[tw] or eleven[tw] or twelve[tw] or month*[tw] or hour*[tw] or day[tw] or days[tw] or “more than”[tw])))) OR pilot[tw]) OR “Pilot Projects”[Mesh]) OR ((clinical trial[pt] or controlled clinical trial[pt] or multicenter study[pt]))) OR ((multicentre[tw] or multicenter[tw] or multi-centre[tw] or multi-center[tw]))) OR (random*[tw] or controlled[tw])) OR ((control[tw] and (area[tw] or cohort*[tw] or compare*[tw] or condition[tw] or design[tw] or group[tw] or groups[tw] or grouping[tw] or intervention*[tw] or participant*[tw] or study[tw])) not (controlled clinical trial[pt] or randomized controlled trial[pt])))) NOT ((((“comment on” or review[tw] or review [pt])) OR ((“Animals”[Mesh] NOT “Humans”[Mesh]))) OR ((rat[tw] or rats[tw] or cow[tw] or cows[tw] or chicken*[tw] or horse[tw] or horses[tw] or mice[tw] or mouse[tw] or bovine[tw] or animal*[tw]))))) OR (clinical trial[pt:noexp] or randomized controlled trial[pt] or controlled clinical trial[pt] or evaluation studies[pt] or comparative study[pt] or intervention studies[mh] or evaluation studies[mh:noexp] or program evaluation[mh:noexp] or random allocation[mh] or random*[tiab] or double blind*[tiab] or controlled trial*[tiab] or clinical trial*[tiab] or pretest*[tiab] or pre test*[tiab] or posttest*[tiab] or post test*[tiab] or prepost*[tiab] or pre post*[tiab] or controlled before*[tiab] or “before and after”[tiab] or interrupted time*[tiab] or time serie*[tiab] or intervention*[tiab]))) AND ((“Neoplasms”[Mesh] OR cancer OR cancers OR neoplasm* OR malignan* OR premalignan* OR precancerous))

This was NOTed with Legare’s original search strategy through 2009 to reduce the number of citations that had to be re-screened.

## EMBASE^®^ (run 10/17/13 and 6/5/2014; citations retrieved: 964)

#14 #8 AND #9 AND #12 AND [humans]/lim AND [embase]/lim AND [article]/lim
#13 #8 AND #9 AND #12
#12 #10 OR #11
#11 random* OR ’double blind’ OR ’controlled trial’/exp OR ’controlled trial’ OR ’clinical trial’/exp OR ’clinical trial’ OR pretest* OR ’pre test’ OR posttest* OR ’post test’ OR prepost* OR pre AND post* ORcontrolled AND before* OR ’before and after’ OR ’interrupted time’ OR ’time series’/exp OR ’time series’ OR intervention*
#10 ‘clinical trial’/exp OR ’clinical trial’ OR ’randomized controlled trial’/exp OR ’randomized controlled trial’ OR ’controlled clinical trial’/exp OR ’controlled clinical trial’ OR ’evaluation’/exp OR ’evaluation’ OR’evaluation studies’/exp OR ’evaluation studies’ OR ’comparative study’/exp OR ’comparative study’ OR intervention AND studies OR ’evaluation’/exp OR ’evaluation’ OR ’evaluation studies’/exp OR’evaluation studies’ OR ’program evaluation’/exp OR ’program evaluation’ OR ’random allocation’/exp OR ’random allocation’
#9 ‘neoplasms’ OR ’neoplasms’/exp OR neoplasms OR ’cancer’ OR ’cancer’/exp OR cancer OR ’cancers’ OR ’cancers’/exp OR cancers OR neoplasm* OR malignan* OR premalignan* OR precancerous
#8 #1 OR #5 OR #6 OR #7
#7 #3 AND #4
#6 #2 AND #4
#5 #2 AND #3
#4 ‘patient’/exp OR patient AND participation OR ’patient’/exp OR patient AND participation* OR ’consumer’/exp OR consumer AND participation* OR ’patient’/exp OR patient AND involvement* OR’consumer’/exp OR consumer AND involvement* OR ’training’/exp OR training AND intervention OR (‘patient’/exp OR patient OR ’patients’/exp OR patients OR consumer* AND (involvement* OR involving* AND participation* OR participating*))
#3 professional OR patient AND relations OR (‘nurses’/exp OR nurses OR ’physicians’/exp OR physicians OR nurse* OR physician* OR clinician* OR doctor* OR general AND practitioner* OR gps OR ‘health’/exp OR health AND care AND professional* OR ’healthcare’/exp OR healthcare AND professional* OR ’health’/exp OR health AND care AND provider* OR ’healthcare’/exp OR healthcare AND provider* OR resident* AND (‘patients’/exp OR patients OR ’patient’/exp OR patient OR consumer* OR people*))
#2 decision AND making OR decision AND support AND techniques OR decision AND support AND systems, AND clinical OR choice AND (‘behaviour’ OR ’behaviour’/exp OR behaviour) OR decision ANDmaking* OR decisionand AND support* OR choice AND behaviour* OR (decision* OR choice* AND (making* OR support* OR behaviour*))
#1 shared AND decision* OR sharing AND decision* OR informed AND decision* OR informed AND choice* OR decision AND aid* OR (share* OR sharing* OR informed* AND (decision* OR deciding*)

## Cochrane Central Register of Controlled Trials (run 10/17/13 and 6/5/2014; citations retrieved: 690)

(((((((shared decision* or sharing decision* or informed decision* or informed choice* or decision aid* or ((share* or sharing* or informed*) and (decision* or deciding* or choice*)))) OR (((decision making or decision support techniques or decision support systems, clinical or choice behaviour or decision making* or decision support* or choice behaviour* or ((decision* or choice*) and (making* or support* or behaviour*)))) AND (patient participation or patient participation* or consumer participation* or patient involvement* or consumer involvement* or “training intervention” or ((patient or patients or consumer*) and (involvement* or involving* or participation* or participating*))))) OR (((decision making or decision support techniques or decision support systems, clinical or choice behaviour or decision making* or decision support* or choice behaviour* or ((decision* or choice*) and (making* or support* or behaviour*)))) AND (professional-patient relations or ((nurses or physicians or nurse* or physician* or clinician* or doctor* or general practitioner* or gps or health care professional* or healthcare professional* or health care provider* or healthcare provider* or resident*) and (patients or patient or consumer* or people*))))) OR (((patient participation or patient participation* or consumer participation* or patient involvement* or consumer involvement* or “training intervention” or ((patient or patients or consumer*) and (involvement* or involving* or participation* or participating*)))) AND (professional-patient relations or ((nurses or physicians or nurse* or physician* or clinician* or doctor* or general practitioner* or gps or health care professional* or healthcare professional* or health care provider* or healthcare provider* or resident*) and (patients or patient or consumer* or people*)))))) AND ((((((((((((((((((((((intervention* or (intervention* and (clinician* or collaborat* or community or complex or DESIGN* or doctor* or educational or family doctor* or family physician* or family practitioner* or financial or GP or general practice* or hospital or hospitals or impact* or improv* or individualize* or individualizing or interdisciplin* or multicomponent or multi-component or multidisciplin* or multi-disciplin* or multifacet* or multi-facet* or multimodal* or multi-modal* or personalize* or personalizing or pharmacies or pharmacist* or pharmacy or physician* or practitioner* or prescrib* or prescription* or primary care or professional* or provider* or regulatory or regulatory or tailor* or target* or team* or usual care )))) OR ((pre-intervention* or preintervention* or “pre intervention*” or post-intervention* or postintervention* or “post intervention*”))) OR ((hospital or patient) and (study or studies or care or health or practitioner* or provider* or physician* or nurse* or nursing or doctor))) OR demonstration project*) OR ((pre-post or “pre test*” or pretest* or posttest* or “post test*” or (pre and post )))) OR ((pre-workshop or post-workshop or (before and workshop ) or (after and workshop )))) OR (trial or ((study and aim*) or “our study”))) OR ((before and (after or during )))) OR ((“quasi-experiment*” or quasiexperiment* or “quasi random*” or quasirandom* or “quasi control*” or quasicontrol* or ((quasi or experimental) and (method or study or trial or design*))))) OR ((“time series” and interrupt*))) OR ((time points and (over or multiple or three or four or five or six or seven or eight or nine or ten or eleven or twelve or month* or hour* or day or days or “more than”)))) OR pilot ) OR “Pilot Projects”) OR ((clinical trial or controlled clinical trial or multicenter study))) OR ((multicentre or multicenter or multi-centre or multi-center ))) OR (random* or controlled )) OR ((control and (area or cohort* or compare* or condition or design or group or groups or grouping or intervention* or participant* or study )) not (controlled clinical trial or randomized controlled trial)))) NOT ((((“comment on” or review or review)) OR ((“Animals” NOT “Humans”))) OR ((rat or rats or cow or cows or chicken* or horse or horses or mice or mouse or bovine or animal*))))) OR (clinical trial or randomized controlled trial or controlled clinical trial or evaluation studies or comparative study or intervention studies or evaluation studies or program evaluation or random allocation or random* or double blind* or controlled trial* or clinical trial* or pretest* or pre test* or posttest* or post test* or prepost* or pre post* or controlled before* or “before and after” or interrupted time* or time serie* or intervention*))) AND ((“Neoplasms” OR cancer OR cancers OR neoplasm* OR malignan* OR premalignan* OR precancerous))

NOT KQ1 strategy to bring down the numbers.

## Cumulative Index to Nursing and Allied Health Literature (CINAHL^®^) and PsycINFO (10/17/13 and 6/5/2014; citations retrieved: CINAHL 716; PsycINFO 301)

S34 S27 AND S33
S33 S28 OR S29 OR S30 OR S31 OR S32
S32 clinical trial or randomized controlled trial or controlled clinical trial or evaluation studies or comparative study or intervention studies or evaluation studies or program evaluation or random allocation or random* or double blind* or controlled trial* or clinical trial* or pretest* or pre test* or posttest* or post test* or prepost* or pre post* or controlled before* or “before and after” or interrupted time* or time serie* or intervention*
S31 (MH “Program Evaluation”)
S30 (MH “Evaluation Research”)
S29 (MH “Experimental Studies”)
S28 (MH “Randomized Controlled Trials”) OR (MH “Clinical Trials”)
S27 S3 AND S26
S26 (S23 OR S24 OR S25)
S25 S12 AND S22
S24 S8 AND S22
S23 S8 AND S12
S22 (S13 OR S21)
S21 S19 AND S20
S20 S14 OR S15 OR S16
S19 (S17 OR S18)
S18 patient or consumer* or people*
S17 (MH “Patients”)
S16 nurse* or physician* or clinician* or doctor* or general practitioner* or gps or health care professional* or healthcare professional* or health care provider* or healthcare provider* or resident*
S15 (MH “Physicians”)
S14 (MH “Nurses”)
S13 (MH “Professional-Patient Relations”) OR (MH “Professional-Client Relations”) OR (MH “Physician-Patient Relations”) OR (MH “Nurse-Patient Relations”)
S12 (S9 OR S10 OR S11)
S11 ((patient or patients or consumer*) and (involvement* or involving* or participation* or participating*))
S10 or patient participation* or consumer participation* or patient involvement* or consumer involvement* or training intervention
S9 (MH “Consumer Participation”)
S8 S5 OR S6 OR S7
S7 choice behaviouror decision making* or decision support* or choice behaviour* or ((decision* or choice*) and (making* or support* or behaviour*))
S6 (MH “Decision Support Techniques+”) OR (MH “Decision Support Systems, Clinical”)
S5 (MH “Decision Making”)
S4 shared decision* or sharing decision* or informed decision* or informed choice* or decision aid* or ((share* or sharing* or informed*) and (decision* or deciding* or choice*))
S3 S1 OR S2
S2 Neoplasms OR cancer OR cancers OR neoplasm* OR malignan* OR premalignan* OR precancerous
S1 (MH “Neoplasms+”)