# Summary of Protocol Amendments

Protocol amendments are summarized in Table 13.

Table 13 Protocol amendments

Date | Section | Original Protocol | Revised Protocol | Rationale
January 10, 2014 | IV. Methods: Grading the Strength of Evidence (SOE) for Individual Comparisons and Outcomes | Please refer to section IV(F), p. 14: Grading the Strength of Evidence (SOE) for Individual Comparisons and Outcomes | Please refer to section IV(F), p. 14: Grading the Strength of Evidence (SOE) for Individual Comparisons and Outcomes | We performed a total rewrite based on input from the Task Order Officer and AHRQ personnel to make explicit the process to be used for grading the SOE, based on the updated chapter in the Methods Guide (2013).
January 10, 2014 | IV. Methods: p. 10 | “We will include only randomized controlled trials (RCTs) and nonrandomized comparative studies (observational, case-control, and cohort studies) of populations, comparisons, interventions, and outcomes that are part of the PICOTS (see above). We will exclude noncomparative studies from this CER,”… | “We will include only full-length reports— excluding conference abstracts and other non-peer reviewed articles— describing final results of randomized controlled trials (RCTs) and non-randomized comparative studies (observational, case-control, and cohort studies) of populations, comparisons, interventions, and outcomes that are part of the PICOTS (see above). We will exclude non-comparative studies from this CER,”… | To make explicit study selection criteria that include only full-length, peer-reviewed evidence

## Review of Key Questions

For all EPC reviews, Key Questions were reviewed and refined as needed by the EPC with input from Key Informants and the Technical Expert Panel to assure that the questions were specific and explicit about what information is being reviewed. In addition, the Key Questions were posted for public comment and finalized by the EPC after review of the comments.

## EPC Team Disclosures

EPC core team members must disclose any financial conflicts of interest greater than $1,000 and any other relevant business or professional conflicts of interest. Related financial conflicts of interest which cumulatively total greater than $1,000 will usually disqualify EPC core team investigators.

## Role of the Funder

This project was funded under Contract No. 290-2007-10058 from the Agency for Healthcare Research and Quality, U.S. Department of Health and Human Services. The Task Order Officer reviewed contract deliverables for adherence to contract requirements and quality. The authors of this report are responsible for its content. Statements in the report should not be construed as endorsement by the Agency for Healthcare Research and Quality or the U.S. Department of Health and Human Services.