# Results

## Overview

In this section, we report our literature search results and PRISMA diagram, which depicts the flow of articles through the review according to our screening and inclusion criteria. We subsequently provide an overview of the design, patients, and study limitations (risk of bias) of all included studies, including relevant studies from CER No. 20. We lay out the results for each Key Question in order, starting with an overview of the relevant current studies, key bulleted points of information, and a synthesis of the evidence when possible. In the results, we did not incorporate formal data synthesis (e.g., meta-analysis) because there was only one randomized trial involving the interventions of interest for treatment of head and neck cancer and the nonrandomized studies were highly heterogeneous and of “poor” quality according to the USPSTF criteria. Finally, we lay out in tabular format the conclusions and evidence base from CER No. 20 and those from this update to qualitatively integrate the findings of both.

## Results of Literature Searches

### Electronic Search

A medical librarian searched MEDLINE^®^, EMBASE^®^, and the Cochrane Controlled Trials Registry for English-language articles. The overall search was performed for a period dating 12 months before the final literature search for CER No. 20 (September 28, 2009) through April 2013. For SBRT, the literature was searched for the period January 1, 1990, through April 2013. The entire search was updated May 1, 2014.

In both searches together, we identified 7,130 unique titles and screened 284 in full text. Of the latter, 15 (N=1,781) met the inclusion criteria, including one RCT (Gupta 2012, N=60).25 In the updated search, we identified a second citation to an RCT (Rathod 2013).26 Because the latter was the same study and included the same patients as the Gupta RCT, it was not double-counted in the total number of patients; however, it reported additional, different outcomes that were reviewed herein and so is counted in that context. Thus, in 14 studies that reported unique data, including the RCT of Rathod,26 3DCRT and IMRT were compared.25,27–39 One study compared 3DCRT and SBRT34; none compared IMRT and SBRT. As in CER No. 20, no evidence was identified on PBT. The flow of articles through the screening and study selection process is shown in the PRISMA diagram (Figure 2).

Figure 2 PRISMA diagram for disposition of literature search results

^a^ Twelve studies addressed both Key Questions 1 and 2.

^b^ Overlapping patient population refers to the studies in which the same patients were included in more than one study. In this case, only one study was included to avoid oversampling. Decision to include a study was based on the clarity in reporting relevant patients and/or outcomes.

Abbreviations: CER = Comparative Effectiveness Review; PRISMA = Preferred Reporting Items for Systematic Reviews and Meta-Analyses.

Figure 2 is a PRISMA diagram illustrating the review of articles identified via literature search for this systematic review. Seven thousand thirty (7,130) records were identified through the literature search. Six thousand eight hundred forty-six (6,846) records were excluded. Two hundred eighty-four (284) titles were screened in full text for eligibility and two hundred sixty-nine (269) were excluded for reasons stated in Appendix C. Fifteen (15) unique articles were included in this report from the literature search.

We note that although CER No. 20 was published in final form in 2010, we had obtained the final data for PARSPORT,40 a key RCT, from the investigators at the time we updated the CER No. 20 literature search. Because the PARSPORT findings appeared in CER No. 20, they were not included in this report.

### Gray Literature (Publication Bias)

The study selection criteria for this update stipulate exclusion of abstracts or other non-peer-reviewed or non-full-length studies. Therefore we did not include any information based on comprehensive searches of meeting abstracts. We examined the bibliographies of all papers screened in full text to identify peer-reviewed articles the electronic search may have missed.

We accessed the Web site ClinicalTrials.gov to identify ongoing phase 3 RCTs that would meet the criteria for inclusion based on our protocol. We identified two phase 3 RCTs of conformal RT in head and neck cancer that are recruiting patients. The first trial (National Clinical Trial [NCT] 01893307) is designed to compare IMRT and PBT in the treatment of oropharyngeal cancer. The primary outcome is the incidence of any late-onset (> 90 days) grade 3 toxicity during the 2 years after completion of RT. The second RCT (NCT01216800) is designed to compare the effects of IMRT and 3DCRT on auditory function (hearing) when used as adjuvant therapy in patients who have undergone surgical resection of parotid tumors. A MEDLINE search of the NCT number(s) and title(s) did not yield any published results; it is unknown whether any data have been reported. Examination of a Scientific Information Packet from one manufacturer of RT equipment did not yield published evidence to add to this update.

### Description of All Included Studies

We identified 15 reports that met the inclusion criteria for this CER update. All are generally described in this section; other details and results specific to a particular Key Question are considered in the relevant subsections to follow.

### Study Limitations

According to the USPSTF criteria for assessing the risk of bias of individual studies, the Gupta RCT was rated “fair,” whereas the 13 nonrandomized studies were rated “poor.” The rationale for the ratings is provided in Table B-1.

We assigned a “fair” USPSTF rating to the Gupta RCT, primarily because the study was not double-blinded, particularly its outcomes assessments. Furthermore, the investigators did not clarify the meaning of their reported “modified intention-to-treat” method. Although this point is for practical purposes moot, because they reported a 97 percent followup rate in each of two study arms, the USPSTF method stipulates assignment of this rating. Gupta reported aggregated survival results in patients with tumors in different sites. However, the distribution of tumor sites and characteristics between arms was similar. Overall, the two study arms were statistically similar and comparable. We note also the report of Rathod and colleagues, a RCT that included the same patients of Gupta but reported additional outcomes. 26 We include evidence from this report but do not double count it in the PRISMA diagram or summations of included evidence. Its risk of bias is identical to that of the Gupta study using the USPSTF system..

The 13 nonrandomized studies were retrospective database analyses, one of which used a historical comparator group. All of the included nonrandomized studies reported results in aggregate, mixing outcomes achieved in heterogeneous groups who may not have received the same treatment(s). Overall, we rated these studies as poor according to the USPSTF criteria.

## Study Design and Patient Characteristics

Table 3 provides a high-level view of the studies included in this update. For comparative purposes, Table 3 also depicts the studies from CER No. 20 that compared 3DCRT and IMRT and reported on clinical outcomes covered herein. We address applicable evidence in more detail in the Discussion section, relating the results and conclusions to those of this update.

Table 3 Design and characteristics of studies included in the CER No. 20 Update and CER No. 20

Investigator (Year) | Comparison | Total No. Patients | RCT | Non-RCT | Mixed Tumor Sites | Single Tumor Site | CCRT | RT ± CCT | CCRT ± Surgery | Postop RT | RT ± CCT± Surgery | rRT ± CCT | USPSTF Study Quality
CER No. 20 Update
Gupta (2012)25 | 3DCRT vs. IMRT | 60 | ● | | ● | | ● | | | | | | Fair
Rathod (2013)26 | 3DCRT vs. IMRT | 60 | ● | | ● | | ● | | | | | | Fair
Al-Mamgani (2013)29 | 3DCRT vs. IMRT | 204 | | ● | | ● | ● | | | | | | Poor
Lambrecht (2013)33 | 3DCRT vs. IMRT | 245 | | ● | ● | | ● | | | | | | Poor
Al-Mamgani (2012)27 | 3DCRT vs. IMRT | 176 | | ● | | ● | | ● | | | | | Poor
Chen (2012)30 | 3DCRT vs. IMRT | 155 | | ● | ● | | | ● | | | | | Poor
Al-Mamgani (2012)28 | 3DCRT vs. IMRT | 82 | | ● | | ● | | | ● | | | | Poor
Dirix (2010)31 | 3DCRT vs. IMRT | 81 | | ● | ● | | | | | ● | | | Poor
Guan (2013)32 | 3DCRT vs. IMRT | 59 | | ● | ● | | | | | | ● | | Poor
Mok (2014)39 | 3DCRT vs. IMRT | 181 | | ● | | ● | | ● | | | | | Poor
Lohia (2014)38 | 3DCRT vs. IMRT | 159 | | ● | | ● | | ● | | | | | Poor
Huang (2013)35 | 3DCRT vs. IMRT | 83 | | ● | | ● | | ● | | | | | Poor
Kruser (2013)37 | 3DCRT vs. IMRT | 178 | | ● | ● | | | | ● | | | | Poor
Kong (2013)36 | 3DCRT vs. IMRT | 67 | | ● | ● | | | | | | ● | | Poor
Ozyigit (2011)34 | 3DCRT vs. SBRT | 51 | | ● | | ● | | | | | | ● | Poor
CER No. 20
Nutting (2011)40 | 3DCRT vs. IMRT | 84 | ● | | | ● | | ● | | | | | Good
Chao (2001)41 | 3DCRT vs. IMRT | 41 | | ● | ● | | | | | | ● | | Poor
Marchal (2004)42 | 3DCRT vs. IMRT | 87 | | ● | ● | | | | | | ● | | Poor
Chen (2007)43 | 3DCRT vs. IMRT | 68 | | ● | ● | | | | | | ● | | Poor
Fang (2007)44 | 3DCRT vs. IMRT | 85 | | ● | | ● | | ● | | | | | Poor
Golen (2007)45 | 3DCRT vs. IMRT | 40 | | ● | ● | | | ● | | | | | Poor
Hodge (2007)46 | 3DCRT vs. IMRT | 195 | | ● | | ● | | ● | | | | | Poor
Rades (2007)47 | 3DCRT vs. IMRT | 44 | | ● | | ● | | | | | ● | | Poor
Fang (2008)48 | 3DCRT vs. IMRT | 203 | | ● | | ● | | ● | | | | | Poor
Gomez (2008)49 | 3DCRT vs. IMRT | 42 | | ● | | ● | | | | | ● | | Poor
Palazzi (2008)50 | 3DCRT vs. IMRT | 137 | | ● | | ● | | | | | ● | | Poor
Rusthoven (2008)51 | 3DCRT vs. IMRT | 87 | | ● | | ● | | ● | | | | | Poor
Vergeer (2009)52 | 3DCRT vs. IMRT | 141 | | ● | | ● | | | | | ● | | Poor
Langendijk (2009)53 | 3DCRT vs. IMRT | 529 | | ● | | ● | | | | | ● | | Poor

Abbreviations: CCRT = concurrent chemoradiotherapy; CCT = concurrent chemotherapy; IMRT = intensity-modulated radiotherapy; PBT = proton-beam radiotherapy; RCT = randomized controlled trial; RT = radiotherapy; rRT = reirradiated radiotherapy; 3DCRT = three-dimensional conformal radiotherapy; USPSTF = United States Preventive Services Task Force.

In total, for the update, 3DCRT and IMRT were compared in 13 studies, including one small (N=60) RCT.25,26 One study compared 3DCRT and SBRT34; none compared IMRT and SBRT. As in CER No. 20, no evidence was identified on PBT. Study details are summarized in Table B-2.

Overall, similar to what we identified for CER No. 20, the body of studies in the update is heterogeneous in terms of tumor site and stage, treatment regimen, and treatment intent (e.g., curative vs. palliative or recurrent). Patients were generally in their mid-fifties, with males predominating across studies. Tumor sites included the hypopharynx, larynx, nasal sinus, nasopharynx, oral cavity, and oropharynx. Four studies involved patients with single tumor sites. The majority of patients across studies had locally advanced (stage III and IV) cancer, although small proportions of patients had stage I or II disease.

Treatment regimens included concurrent chemoradiotherapy (CCRT); RT with or without concurrent chemotherapy (CCT); CCRT with or without surgery; and adjuvant postoperative RT. Where it appears in all tables throughout this update, the term RT ± CCT refers to treatment regimens in which all patients received RT, but not all received CCT. This is distinct from CCRT, in which all patients were reported to have received RT and chemotherapy concurrently. We did not abstract information on specific chemotherapy regimens or surgical procedures; they are beyond the scope of this update. As summarized in Table B-3, ionizing radiation was delivered by 3DCRT or IMRT to a total dose of 60–74 Gy using conventional fractionation schedules, which are typical of 3DCRT and IMRT (30–35 fractions, 2 Gy per fraction for 5–7 weeks); SBRT was delivered in a similar total dose but in five single fractions. We did not abstract or report on RT protocols in detail because they also are beyond the proposed scope of the review.

## Key Question 1 Comparative Effectiveness of 3DCRT, IMRT, SBRT, and PBT Regarding Adverse Events and QOL

### Overview

Tables 4 and 5 depict key comparative acute (< 90 days post-treatment) and late (> 90 days post-treatment) toxicity outcomes reported by each relevant study; a blank cell in any table means that the toxicity was not reported in that study. Acute and late toxicity outcomes were not collected consistently across studies. Only eight (53%) studies reported acute toxicities.25,27,29,31,33,36–38 Nine (60%) studies reported late toxicities.25,27–29,31,33,34,36,39 Only two studies reported QOL evidence according to RT modality, including the RCT by Rathod.26

Table 4 Summary of key reported acute (<90 days post-treatment) comparative toxicity outcomes

Study (Year) | Study Design (USPSTF Rating) | RT Modalities (N) | Treatment Regimen | Tumor Site(s) | Dermatitis | Dysphagia | Mucositis | Nausea | Pain | Salivary Glands | Weight Loss | Other
Gupta (2012)25 | RCT (fair) | 3DCRT (28) IMRT (32) | CCRT | Hypopharynx Larynx Oropharynx | ● | ● | ● | | | ● | ●
Al-Mamgani (2013)29 | Comparative Retrospective (poor) | 3DCRT (65) IMRT (139) | CCRT | Oropharynx | ● | ● | ● | | ●
Lambrecht (2013)33 | Comparative Retrospective (poor) | 3DCRT (135) IMRT (110) | CCRT | Hypopharynx Larynx Nasopharynx Oral cavity Oropharynx | | ● | ● | | | | | Erythema
Al-Mamgani (2012)27 | Comparative Retrospective (poor) | 3DCRT (62) IMRT (114) | RT ± CCT | Hypopharynx | ● | ● | ● | | ● | | | Neutropenic fever Intercurrent infection Severe malaise
Dirix (2010)31 | Comparative Prospective (IMRT) Retrospective (3DCRT) (poor) | 3DCRT (41) IMRT (40) | Postoperative RT | Nasal cavity Paranasal sinus | ● | ● | ● | | ● | ● | | Smell Taste Fatigue Conjunctivitis Dry eye Tearing Alopecia Tinnitus Serous otitis Blurred vision
Kong (2013)36 | Comparative Retrospective (poor) | 3DCRT (37) IMRT (30) | RT ± CCT± surgery | Hypopharynx Larynx Nasopharynx Oral cavity Oropharynx Paranasal sinus | | ● | ● | | | ●
Lohia (2014)38 | Comparative Retrospective (poor) | 3DCRT (56) IMRT (103) | RT ± CCT | Oropharynx | ● | | ● | | | ● | ● | Larynx Pharynx Death
Kruser (2013)37 | Comparative Prospective (poor) | 3DCRT (41) IMRT (137) | CCRT ± surgery | Hypopharynx Larynx Nasopharynx Oral cavity Oropharynx Unknown primary | | | ● | | | | | Hematologic toxicities: hemoglobin, leukocyte & platelet counts

Abbreviations: CCRT = concurrent chemoradiotherapy; CCT = concurrent chemotherapy; IMRT = intensity-modulated radiotherapy; PBT = proton-beam radiotherapy; RCT = randomized controlled trial; RT = radiotherapy; rRT = reirradiated radiotherapy; SBRT = stereotactic body radiotherapy; 3DCRT = three-dimensional conformal radiotherapy; USPSTF = United States Preventive Services Task Force.

Table 5 Summary of key reported late (>90 days post-treatment) comparative toxicity outcomes

Study (Year) | Study Design (USPSTF Rating) | RT Modalities (N) | Treatment Regimen | Tumor Site(s) | Dysphagia | Mucositis | Pain | Skin | Salivary Glands | Subcutaneous | Xerostomia | Other
Gupta (2012)25 | RCT (fair) | 3DCRT (28) IMRT (32) | CCRT | Hypopharynx Larynx Oropharynx | | | | | ● | ● | ●
Al-Mamgani (2013)29 | Comparative Retrospective (poor) | 3DCRT (65) IMRT (139) | CCRT | Oropharynx | ● | ● | ● | ● | | ● | ●
Lambrecht (2013)33 | Comparative Retrospective (poor) | 3DCRT (135) IMRT (110) | CCRT | Hypopharynx Larynx Nasopharynx Oral cavity Oropharynx | ● | | | | | | ●
Al-Mamgani (2012)27 | Comparative Retrospective (poor) | 3DCRT (62) IMRT (114) | RT ± CCT | Hypopharynx | ● | ● | ● | ● | | ● | ● | Cartilage necrosis Esophagus
Al-Mamgani (2012)28 | Comparative Retrospective (poor) | 3DCRT (25) IMRT (57) | CCRT ± surgery | Paranasal sinus | ● | | | | | | ● | Osteoradionecrosis Nasolacrimal duct Stenosis Ectropion Entropion Blindness Trismus Deafness
Dirix (2010)31 | Comparative Prospective (IMRT) Retrospective (3DCRT) (poor) | 3DCRT (41) IMRT (40) | Postoperative RT | Nasal cavity Paranasal sinus | | ● | ● | ● | ● | | ● | Dry eye syndrome Neuropathy
Kong (2013)36 | Comparative Retrospective (poor) | 3DCRT (37) IMRT (30) | RT ± CCT± surgery | Hypopharynx Larynx Nasopharynx Oral cavity Oropharynx Paranasal sinus | ● | | | | | | ●
Lohia (2014)38 | Comparative Retrospective (poor) | 3DCRT (56) IMRT(103) | RT ± CCT | Oropharynx | | | | | | | | PEG tube dependence
Mok (2014)39 | Comparative Retrospective (poor) | 3DCRT (90) IMRT (91) | RT ± CCT | Hypopharynx | ● | | | | | | | Esophageal stenosis Larynx preservation PEG tube dependence

Abbreviations: CCRT = concurrent chemoradiotherapy; CCT = concurrent chemotherapy; IMRT = intensity-modulated radiotherapy; PBT = proton-beam radiotherapy; PEG = percutaneous endoscopic gastrostomy; RCT = randomized controlled trial; RT = radiotherapy; rRT = reirradiated radiotherapy; SBRT = stereotactic body radiotherapy; 3DCRT = three-dimensional conformal radiotherapy; USPSTF = United States Preventive Services Task Force.

a The study involved reirradiation of recurrent head-and-neck cancer tumors.

Because toxicities were inconsistently reported, we focused this update, as we did CER No. 20, on those toxicities prominently associated with RT in the head and neck: dysphagia, salivary gland function, and xerostomia. We also only consider toxicities of grade 2 or greater according to accepted criteria, such as those of the Radiation Therapy Oncology Group or the NCI Common Terminology Criteria for Adverse Events. Grades greater than 2 are those that have direct impact on patient outcomes and can adversely affect treatment delivery.

Patients in all studies, except that of Dirix (2010),31 received chemotherapy as part of treatment; those treated by Dirix received postoperative RT. In general, investigators did not adjust results to account for chemotherapy-associated toxicities independent of RT-associated toxicities, which complicates interpretation of toxicity evidence for many adverse events (e.g., mucositis). This is somewhat ameliorated by our focus on studies in which chemotherapy regimens are similar between study arms, thus potentially isolating the effect of the RT modality on such outcomes.

### Key Points

- The results of primary interest for this Key Question comprise comparative acute (< 90 days) and late (> 90 days) radiation-associated dysphagia, salivary gland dysfunction, xerostomia, and QOL.
- New comparative evidence assessed in this update strengthens the conclusion from CER No. 20 that the risk of grade 2 or higher late xerostomia is significantly lower in patients treated with IMRT than with 3DCRT.
- Although we identified evidence on other key toxicities (e.g., mucositis, dysphagia, skin toxicities, osteoradionecrosis of the jaw) and QOL, the reported rates compared between modalities were inconsistent. Thus, evidence on adverse events other than late xerostomia remains insufficient to alter conclusions of CER No. 20.
- Post-treatment toxicities were reported inconsistently across studies, precluding comparisons within the body of evidence. We are uncertain whether the limited evidence on RT-associated toxicities overall reflects their absence or that the investigators did not systematically collect or chose not to report them.
- The best quality evidence comprises one small (N=60), fair quality RCT (Gupta, 2012) in which 3DCRT and IMRT were compared in a regimen of CCRT to treat patients with cancer of the hypopharynx, larynx, and oropharynx. Key findings of this study relevant to Key Question 1 pertained to late xerostomia and salivary gland dysfunction.
- One nonrandomized, poor quality study of 3DCRT versus SBRT did not report on primary outcomes for Key Question 1.
- One fair quality study and one poor quality nonrandomized study reported QOL outcomes related to treatment with 3DCRT or IMRT

### Qualitative Synthesis

In Table 6, we aggregate new comparative evidence related to Key Question 1 on toxicities actually reported in studies according to the intervention comparison, treatment regimen, and timeframe (acute vs. long-term). We identified no evidence from patients stratified according to tumor site(s), so we did not include tumor information in this table. Although we collected evidence on lesser NCI Common Terminology Criteria for Adverse Events or Radiation Therapy Oncology Group grades, as shown in Tables B-4 and B-5, here we present grade 2 or higher toxicities, which are likely to adversely impact patient management, hospitalization, and survival outcomes. The last two columns of Table 6 show reported proportions for each toxicity and any statistically significant results by study if so achieved.

Table 6 Key Question 1: Qualitative evidence synthesis for key reported comparative grade 2 or higher toxicity outcomes and QOL

Intervention | Comparator | Treatment Regimen | Outcome | Timeframe | Number of Studies (Number of Patients) | Reported Rates Across Studies (%) | Individual Study Statistically Significant Results (p-Value)
3DCRT | IMRT | CCRT | Dysphagia | Acute | Three studies25,29,33 (N=509) | 3DCRT: 0%–84% IMRT: 9.5%–76% | Only one study showed a statistically significant benefit of IMRT vs. 3DCRT (grade ≥ 2) 3DCRT: 84% IMRT: 49% (p=0.04)29
3DCRT | IMRT | CCRT | Dysphagia | Late | Two studies29,33 (N=707) | 3DCRT: 30%, 34% IMRT: 20%, 38% | Only one study showed a statistically significant benefit of IMRT vs. 3DCRT (grade ≥ 2) 3DCRT: 30% IMRT: 20% (p=0.04)29
3DCRT | IMRT | RT ± CCT | Dysphagia | Acute | One study27 (N=176) | 3DCRT: 47% IMRT: 36% | Not significant
3DCRT | IMRT | RT ± CCT | Dysphagia | Late | Two studies27,39 (N=357) | 3DCRT: 10% IMRT: 1% | Only one study showed a statistically significant benefit of IMRT vs. 3DCRT (grade ≥ 2) 3DCRT: 10% IMRT: 1% (p=0.02)27 The Mok 2014 study39 does not present quantitative data pertaining to late dysphagia of 3DCRT vs. IMRT therapies other than to report there was no statistically significant difference between arms.
3DCRT | IMRT | CCRT ± surgery | Dysphagia | Late | One study28 (N=82) | 3DCRT: 12% IMRT: 5% | Not significant
3DCRT | IMRT | RT ± CCT± surgery | Dysphagia | Acute | One study36 (N=67) | 3DCRT: 84% IMRT: 80% | Not significant
3DCRT | IMRT | RT ± CCT± surgery | Dysphagia | Late | One study36 (N=67) | 3DCRT: 23% IMRT: 54% | p=0.02
3DCRT | IMRT | Postoperative RT | Dysphagia | Acute | One study31 (N=81) | 3DCRT (any grade): 34% IMRT (grade 2): 7.5% | p=0.003
3DCRT | IMRT | CCRT | Salivary glands | Acute | One study25 (N=60) | 3DCRT (grade 2): 89% IMRT (grade 2): 59% | p=0.03
3DCRT | IMRT | RT ± CCT | Salivary glands | Acute | One study38 (N=159) | 3DCRT: Not quantitated IMRT: Not quantitated | Not significant The Lohia 2014 study38 does not present quantitative data pertaining to acute salivary glands toxicity of 3DCRT vs. IMRT therapies other than to report there was no statistically significant difference between arms
3DCRT | IMRT | Postoperative RT | Salivary glands | Acute | One study31 (N=81) | 3DCRT (any grade): 90% IMRT (grade 2): 0.0% | p<0.001
3DCRT | IMRT | CCRT | Xerostomia | Late | Three studies25,29,33 (N=509) | 3DCRT (grade > 2): 49–77% IMRT (grade > 2): 23–33% | All three studies showed statistically significant benefit of IMRT vs. 3DCRT: p=0.001, p=0.002, p<0.001
3DCRT | IMRT | RT ± CCT | Xerostomia | Late | One study27 (N=176) | 3DCRT (grade 2): 24% IMRT (grade 2): 11% | p=0.009
3DCRT | IMRT | CCRT ± surgery | Xerostomia | Late | One study28 (N=82) | 3DCRT (grade > 2): 16% IMRT (grade > 2): 7% | Not significant
3DCRT | IMRT | RT ± CCT± surgery | Xerostomia | Acute | One study36 (N=67) | 3DCRT (grade ≥ 2): 46% IMRT (grade ≥ 2): 67% | Not significant
3DCRT | IMRT | RT ± CCT± surgery | Xerostomia | Late | One study36 (N=67) | 3DCRT (grade ≥ 2): 94% IMRT (grade ≥ 2): 40% | p=0.004
3DCRT | IMRT | Postoperative RT | Xerostomia | Late | One study31 (N=81) | 3DCRT (any grade): 34% IMRT (grade 2): 0.0% | p=0.03
3DCRT | IMRT | CCRT | QOL | Acute and Late | Two studies26,30 (N=215) | The RCT of Rathod26 showed statistically significant benefit for IMRT in head and neck cancer specific domains of scales and dry mouth, sticky saliva, swallowing, for at least one time point. No QOL endpoints were worse with IMRT than with 3DCRT at any time point in the Rathod study. In the other study 30, use of IMRT was the only variable associated with improved QOL. | p<0.05 p<0.01

Abbreviations: CCRT = concurrent chemoradiotherapy; CCT = concurrent chemotherapy; IMRT = intensity-modulated radiotherapy; RT = radiotherapy; 3DCRT = three-dimensional conformal radiotherapy.

#### RT-Associated Toxicities

Results from one nonrandomized study show a statistically significant lower rate of acute dysphagia (49 percent vs. 84 percent, respectively, p=0.04) with IMRT compared with 3DCRT in a regimen of CCRT.29 The Gupta25 RCT showed a lower rate of acute dysphagia with 3DCRT (0 percent) than with IMRT (9.5 percent), although the difference was nonsignificant (p=0.21). Significantly reduced rates of late dysphagia were reported in single studies of IMRT compared with 3DCRT in a regimen of CCRT29 or RT with or without CCT.27 Two individual studies showed a reduced rate of acute salivary gland dysfunction with IMRT compared with 3DCRT in a regimen of CCRT25 or postoperative RT,31 respectively.

As shown in Table 6, all three studies of IMRT compared with 3DCRT in a regimen of CCRT showed statistically significant reduction in late xerostomia.25,29,33 The rate of late xerostomia also was significantly lower with IMRT than with 3DCRT in single studies in a regimen of RT with or without CCT,27 or postoperative RT,28 respectively.

#### RT-Associated QOL

One RCT reported QOL evidence on IMRT versus 3DCRT in a regimen of RT with CCT.26 Rathod et al. reported on mean QOL scores using the European Organization for Research and Treatment of Cancer QOL questionnaire (QLQ-C30) and Head-Neck module (HN-35) validated, self-administered tools at baseline (pretreatment) and periodically on follow-up (3, 6, 12, 18, and 24 months). The study reported global QOL was not significantly affected by RT technique. Treatment with IMRT showed a benefit to some general QOL domains, as well as several head and neck cancer-specific domains, as compared with 3DCRT. General domains toward which IMRT demonstrated a significant benefit included: emotional functioning at 12 months (p=0.008), role functioning at 12 months (p=0.008), and social contact at 24 months (p=0.03). Head and neck cancer-specific symptoms for which IMRT demonstrated a significant benefit (p<0.05) compared with 3DCRT included scales and dry month (6, 12, and 18 months), as well as opening mouth (6 and 24 months). Sticky saliva, pain, swallowing, senses, sexuality, feeling ill, and insomnia tended to be ameliorated by use of IMRT compared with 3DCRT, and were all statistically significant for at least one time point. No QOL domains were worse with IMRT than with 3DCRT at any time point. Among both RT techniques, QOL domains generally experienced maximal deterioration after RT, followed by a trend toward gradual recovery over time.

One nonrandomized study reported QOL evidence on IMRT versus 3DCRT in a regimen of RT with or without CCT. Chen et al. reported on mean QOL scores using the University of Washington Quality of Life validated, self-administered tool.30 In this study, the salivary gland domain was the only specific component of this score wherein significant differences were observed between the IMRT and the 3DCRT groups at both 1 and 2 years (p<0.001 at both points). Other domains (pain, appearance, activity, recreation, swallowing, chewing, speech, shoulder, taste, saliva, mood, anxiety) showed no differences according to RT modality. At 1 year after completion of RT, the global QOL was rated as “very good” or “outstanding” among 51 percent of patients treated with IMRT compared with 41 percent of those treated with 3DCRT (p=0.11). However, at 2 years, the corresponding percentages were 73 percent and 49 percent, respectively (p<0.001), showing a benefit of IMRT. Multivariate analysis showed no effect on QOL scores of age, sex, radiation intent, radiation dose, T stage, primary site, or use of CCT and neck dissection. Use of IMRT was the only variable associated with improved QOL (p<0.01).

### Strength of Evidence for Key Question 1

To evaluate the SOE, we used an approach specifically developed by the AHRQ EPC program and referenced in the “Methods Guide.”20 This approach is based on a system initially described by the GRADE Working Group. It explicitly addresses four required domains: risk of bias, directness, consistency, and precision, as outlined in the Methods section.

Table 7 shows the SOE for new evidence on the comparative effects on QOL and toxicities of 3DCRT, IMRT, SBRT, and PBT in the treatment of head and neck cancer patients.

Table 7 SOE for Key Question 1: Adverse effects and QOL

Intervention | Comparator | Treatment Regimen | Outcome | Evidence Base (Number of Patients) | Study Limitations (Risk of Bias) | Directness | Consistency | Precision | Overall SOE
3DCRT | IMRT | CCRT | Late xerostomia | Three studies including one RCT25,29,33 (N=509) | Moderate One “fair” quality small RCT (N=60, Gupta25) plus two “poor” quality non-randomized studies result in a “moderate” study limitations rating | Direct All three studies directly compared IMRT and 3DCRT. | Consistent All three studies showed a statistically significant reduction of late grade > 2 xerostomia with IMRT compared with 3DCRT (p=0.001, p<0.002, p<0.001) | Precise | Moderate The body of evidence comprises one RCT, for a provisional SOE of “high”. We downgraded the SOE one level based on the “moderate” risk of bias of the body of evidence. Although the Gupta trial25 was relatively small, its statistically significant result coupled with similar findings of the much larger nonrandomized evidence merits an overall SOE rating of moderate. The overall SOE was rated as moderate due to limitations in the methodological quality of the studies. However, the findings of the three studies were consistent and indicated statistical significance.
3DCRT | IMRT | RT ± CCT | Late xerostomia | One study27 (N=176) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | CCRT ± surgery | Late xerostomia | One study28 (N=82) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | RT ± CCT± surgery | Acute xerostomia | One study36 (N=67) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | RT ± CCT± surgery | Late xerostomia | One study36 (N=67) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | Postoperative RT | Late xerostomia | One study31 (N=81) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | CCRT | Acute dysphagia | Three studies, including one RCT25,29,33 (N=509) | Moderate One “fair” quality small RCT (N=60, Gupta25) plus two “poor” quality nonrandomized studies result in a “moderate” study limitations rating. | Direct | Inconsistent One non-randomized study showed a statistically significant reduction with IMRT (49%) compared with 3DCRT (84%).29 The other non-RCT showed a directionally same but nonsignificant effect that favored IMRT over 3DCRT. The Gupta25 RCT showed a lower but also nonsignificant rate difference of acute dysphagia with 3DCRT (0%) compared with IMRT (9.5%) (p=0.21). | Imprecise The Gupta RCT25 only included 60 cases, compared with 449 for the other 2 studies. It was likely not sufficiently powered to detect slight changes in rates of adverse effects, particularly in the face of much larger, albeit “poor” quality non-RCT evidence. | Insufficient A “high” provisional SOE based on the Gupta RCT25 was reduced three levels for three reasons: (1) inconsistent rating; (2) imprecise rating based on the small size of the Gupta RCT and its nonsignificant result; and (3) the two nonrandomized studies were of “poor” quality, heterogeneous, and subject to a high risk of bias, thus increasing the risk of bias to “moderate” for the body of evidence.
3DCRT | IMRT | CCRT | Late dysphagia | Two studies29,33 (N=707) | High Two “poor” quality, nonrandomized studies comprise the body of evidence. | Direct | Inconsistent One study showed a statistically significant effect (p=0.03) of IMRT compared with 3DCRT, with the second study showing a reduction, albeit nonsignificant reduction. | Precise | Insufficient The two nonrandomized studies were “poor” quality and heterogeneous, with high risk of bias that compromises the value of their results.
3DCRT | IMRT | CCRT | QOL | Two studies26,30 (N=215) | Moderate One “fair” quality small RCT (N=60, Rathod 2013^26^) plus one “poor” quality nonrandomized study result in a “moderate” study limitations rating. | Direct | Inconsistent One study showed a statistically significant benefit (p<0.001) of IMRT compared with 3DCRT as it pertains to global QOL at 1 and 2 years,30 while the second study reports no statistical difference based on radiotherapy technique. | Imprecise The Rathod RCT26 only included 60 cases, compared with 155 for the second study. It was likely not sufficiently powered to detect slight changes in QOL, particularly in the face of much larger, albeit “poor” quality non-RCT evidence. | Insufficient A “high” provisional SOE based on the Rathod RCT26 was reduced three levels for three reasons: (1) inconsistent rating; (2) imprecise rating based on the small size of the Rathod RCT and its nonsignificant result; and (3) the nonrandomized study was of “poor” quality, heterogeneous, and subject to a high risk of bias, thus increasing the risk of bias to “moderate” for the body of evidence.
3DCRT | IMRT | RT ± CCT | Acute dysphagia | One study27 (N=176) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | RT ± CCT | Late dysphagia | Two studies27,39 (N=357) | High Two “poor” quality, nonrandomized studies comprise the body of evidence. | Direct | Inconsistent One study showed a statistically significant effect (p=0.02) of IMRT compared with 3DCRT, with the second study showing no statistically significant difference. | Imprecise | Insufficient The two nonrandomized studies were “poor” quality, heterogeneous, and with a high risk of bias that compromises the value of their results.
3DCRT | IMRT | CCRT ± surgery | Late dysphagia | One study28 (N=82) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | RT ± CCT± surgery | Acute dysphagia | One study36 (N=67) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | RT ± CCT± surgery | Late dysphagia | One study36 (N=67) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | Postoperative RT | Acute dysphagia | One study31 (N=81) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | CCRT | Acute salivary gland dysfunction | One study25 (N=60) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | RT ± CCT | Acute salivary gland dysfunction | One study38 (N=159) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | Postoperative RT | Acute salivary gland dysfunction | One study31 (N=81) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | SBRT PBT | Any regimen | Any outcome | No evidence | No evidence | No evidence | No evidence | No evidence | No evidence
IMRT | SBRT PBT | Any regimen | Any outcome | No evidence | No evidence | No evidence | No evidence | No evidence | No evidence

Abbreviations: CCT = concurrent chemotherapy; CCRT = concurrent chemoradiotherapy; IMRT = intensity-modulated radiotherapy; PBT = proton-beam radiotherapy; RCT = randomized controlled trial; RT = radiotherapy; SBRT = stereotactic body radiotherapy; SOE = strength of evidence; 3DCRT = three-dimensional conformal radiotherapy.

The evidence we identified for this update supports an SOE rating of “moderate” for the comparison of 3DCRT and IMRT in a regimen of CCRT, showing a benefit of IMRT in significantly reducing the incidence of late grade 2 or higher xerostomia. Two other studies showed a statistically significant reduction in the incidence of late grade 2 or higher xerostomia in two other treatment regimens (RT with or without CCT, postoperative RT). New evidence on any other RT-associated toxicity is insufficient to form conclusions on a benefit or harm of 3DCRT compared with IMRT.

## Key Question 2 Comparative Effectiveness of 3DCRT, IMRT, SBRT, and PBT Regarding Tumor Control and Patient Survival

### Overview

In this section we summarize evidence on comparative oncologic outcomes for different RT types. As noted in the Methods section, we did not seek evidence from other study designs (e.g., single-arm observational) that may report additional outcomes not captured in the comparative studies.

Table 8 depicts key oncologic outcomes reported by each relevant study; a blank cell in each table means the outcome was not reported in that study. Not all outcomes were collected in each study. Outcomes of primary interest are overall survival, local control (no evidence of primary tumor), or locoregional control (no evidence of primary tumor or regional metastatic spread) among patients treated with IMRT compared with 3DCRT. Other oncologic outcomes were inconsistently reported across the body of studies, as shown in Table 8.

Table 8 Summary of key reported comparative oncologic outcomes

Study (Year) | Study Design (USPSTF Rating) | RT Modalities (N) | Treatment Regimen | Tumor Site(s) | Overall Survival | Cancer-Specific Survival | Disease-Free Survival | Local Control | Loco-regional Control | Distant Control | Other
Gupta (2012)25 | RCT (fair) | 3DCRT (28) IMRT (32) | CCRT | Hypopharynx Larynx Oropharynx | ● | | | | ●
Rathod (2013)26 | RCT (fair) | 3DCRT (28) IMRT (32) | CCRT | Hypopharynx Larynx Oropharynx | ● | | | | ●
Al-Mamgani (2013)29 | Comparative Retrospective (poor) | 3DCRT (65) IMRT (139) | CCRT | Oropharynx | ● | ● | ● | ● | ●
Lambrecht (2013)33 | Comparative Retrospective (poor) | 3DCRT (135) IMRT (110) | CCRT | Hypopharynx Larynx Nasopharynx Oral cavity Oropharynx | ● | | | | ●
Al-Mamgani (2012)27 | Comparative Retrospective (poor) | 3DCRT (62) IMRT (114) | RT ± CCT | Hypopharynx | | | | | | | ●
Chen (2012)30 | Comparative Retrospective (poor) | 3DCRT (71) IMRT (84) | RT ± CCT | Hypopharynx Larynx Nasopharynx Oropharynx Unknown primary | | | | | | | ●
Al-Mamgani (2012)28 | Comparative Retrospective (poor) | 3DCRT (25) IMRT (57) | CCRT ± surgery | Paranasal sinus | | | | ●
Dirix (2010)31 | Comparative Prospective (IMRT) Retrospective (3DCRT) (poor) | 3DCRT (41) IMRT (40) | Postoperative RT | Nasal cavity Paranasal sinus | ● | | ● | ● | | ●
Mok (2014)39 | Comparative Retrospective (poor) | 3DCRT (90) IMRT (91) | RT ± CCT | Hypopharynx | ● | | | | ● | ●
Lohia (2014)38 | Comparative Retrospective (poor) | 3DCRT (56) IMRT (103) | RT ± CCT | Oropharynx | ● | | ● | | | | ●
Huang (2013)35 | Comparative Retrospective (poor) | 3DCRT (53) IMRT (30) | RT ± CCT | Nasopharynx | ● | | ● | | ●
Guan (2013)32 | Comparative Retrospective (poor) | 3DCRT (16) IMRT (43) | RT ± CCT ± surgery | Nasal cavity Paranasal sinus | | | | | ● | | ●
Kong (2013)36 | Comparative Retrospective (poor) | 3DCRT (37) IMRT (30) | RT ± CCT± surgery | Hypopharynx Larynx Nasopharynx Oral cavity Oropharynx Paranasal sinus | ● | | | | ● | ●
Ozyigit (2011)34 | Comparative Retrospective (poor) | 3DCRT (27) SBRT (24) | rRT ± CCT | Nasopharynx | ● | ● | | ●

Abbreviations: 3DCRT = three-dimensional conformal radiotherapy; CCT = concurrent chemotherapy; CCRT = concurrent chemoradiotherapy; IMRT = intensity-modulated radiotherapy; RCT = randomized controlled trial; RT = radiotherapy; rRT = reirradiated radiotherapy; SBRT = stereotactic body radiotherapy; USPSTF = United States Preventive Services Task Force.

### Key Points

- The results of primary interest for this Key Question comprise overall survival, local control, and locoregional control.
- As we found in CER No. 20, comparative evidence assessed in this update was insufficient to draw relative conclusions on any oncologic outcomes.
- The key oncologic outcomes were not reported universally across studies, so we could not make comparisons across a larger body of evidence.
- The best quality evidence comprises one small (N=60), fair quality RCT (Gupta, 2012) in which 3DCRT and IMRT were compared in a regimen of CCRT to treat patients with cancer of the hypopharynx, larynx and oropharynx.
- Two additional nonrandomized, poor quality studies reported on the key oncologic outcomes with 3DCRT and IMRT in a regimen of CCRT among patients with cancer of the hypopharynx, larynx, oral cavity, nasopharynx, and oropharynx.
- One study of 3DCRT versus SBRT reported overall survival and local control in a regimen of RT with or without CCRT among patients with nasopharyngeal cancer. However, 22 percent of unidentified patients in the 3DCRT arm received concurrent high-dose rate brachytherapy so the oncologic outcomes are not included in this synthesis.

### Qualitative Synthesis

In Table 9, we have aggregated new evidence related to Key Question 2 on comparative oncologic outcomes actually reported in studies according to the intervention comparison, treatment regimen, and timeframe. We identified no evidence from patients stratified according to tumor site(s), so we have not included tumor information in this table. Further, we did not identify any evidence on differences in oncologic outcomes related to the HPV status of patient tumors. The last two columns of Table 9 show reported proportions for each outcome and statistically significant results if attained.

Table 9 Key Question 2: Qualitative evidence synthesis for key reported comparative oncologic outcomes

Intervention | Comparator | Treatment Regimen | Outcome | Number of Studies (Number of Patients) | Reported Rates Across Studies (%) | Individual Study Statistically Significant Results (p-Value)
3DCRT | IMRT | CCRT | Overall survival | Three studies (four reports)25–27,33 (N=509) | [underlined: 3 years] (2 studies) 3DCRT: 71%, 61% IMRT: 68%, 64% [underlined: 5 years] (1 study) 3DCRT: 43% IMRT: 47% | No statistically significant difference in overall survival was reported in any study.
3DCRT | IMRT | CCRT | Local control | One study29 (N=204) | [underlined: 5 years] 3DCRT: 74% IMRT: 82% | No statistically significant difference in local control was reported.
3DCRT | IMRT | CCRT | Locoregional control | Two studies (three reports)25,26,33 (N=305) | [underlined: 3 years] 3DCRT: 88%, 71% IMRT: 81%, 70% | No statistically significant difference in locoregional control was reported in either study.
3DCRT | IMRT | CCRT | Disease-free survival | One study29 (N=204) | [underlined: 5 years] 3DCRT: 58% IMRT: 60% | No statistically significant difference in disease-free survival was reported.
3DCRT | IMRT | CCRT ± surgery | Local control | One study28 (N=82) | [underlined: 5 years] 3DCRT: 64% IMRT: 80% | No statistically significant difference in local control was reported.
3DCRT | IMRT | Postoperative RT | Overall survival | One study31 (N=81) | [underlined: 2 years] 3DCRT: 73% IMRT: 89% | No statistically significant difference in overall survival was reported.
3DCRT | IMRT | Postoperative RT | Local control | One study31 (N=81) | [underlined: 2 years] 3DCRT: 67% IMRT: 76% | No statistically significant difference in local control was reported.
3DCRT | IMRT | Postoperative RT | Disease-free survival | One study31 (N=81) | [underlined: 2 years] 3DCRT: 60% IMRT: 72% | p=0.02
3DCRT | IMRT | RT ± CCT ± surgery | Overall survival | One study36 (N=67) | [underlined: 1 year] 3DCRT: 94% IMRT: 97% [underlined: 2 years] 3DCRT: 87% IMRT: 97% | No statistically significant difference in overall survival was reported.
3DCRT | IMRT | RT ± CCT ± surgery | Locoregional control | One study36 (N=67) | [underlined: 1 year] 3DCRT: 61% IMRT: 89% [underlined: 2 years] 3DCRT: 58% IMRT: 80% | p=0.029
3DCRT | IMRT | RT ± CCT ± surgery | Distant metastasis-free survival | One study31 (N=67) | [underlined: 1 year] 3DCRT: 86% IMRT: 92% [underlined: 2 years] 3DCRT: 82% IMRT: 75% | No statistically significant difference in distant metastasis-free survival was reported.
3DCRT | IMRT | RT ± CCT | Overall survival | Three studies35,38,39 (N=423) | [underlined: 2 years] (1 study) 3DCRT: 58% IMRT: 35% [underlined: 3 years] (1 study) 3DCRT: 52% IMRT: 50% [underlined: 5 years] (1 study) 3DCRT: 50% IMRT: 89% | The Huang study35 reports a statistically significant benefit of IMRT vs. 3DCRT as it pertains to 5-year overall survival (p=0.004). No statistically significant difference in overall survival was reported at 2- or 3-years in the other two studies.
3DCRT | IMRT | RT ± CCT | Locoregional control | Two studies35,39 (N=264) | [underlined: 3 years] (1 study) 3DCRT: 58% IMRT: 75% [underlined: 5 years] (1 study) 3DCRT: 54% IMRT: 75% | The Mok study39 reports a statistically significant benefit of IMRT vs. 3DCRT as it pertains to 3-year locoregional control (p=0.003). The Huang study35 reports a statistically significant benefit of IMRT vs. 3DCRT as it pertains to 5-year locoregional control (p=0.018).
3DCRT | IMRT | RT ± CCT | Distant relapse | One study35,39 (N=181) | [underlined: 3 years] 3DCRT: 20% IMRT: 23% | No statistically significant difference in distant relapse was reported.
3DCRT | IMRT | RT ± CCT | Disease-free survival | Two studies35,38 (N=242) | [underlined: 2 years] (1 study) 3DCRT: 66% IMRT: 59% [underlined: 5 years] (1 study) 3DCRT: 47% IMRT: 69% | No statistically significant difference in disease-free survival was reported by the Lohia study at 2 years.38 The Huang study35 reports a statistically significant benefit of IMRT vs. 3DCRT as it pertains to 5-year disease-free survival (p=0.046).

Abbreviations: CCRT = concurrent chemoradiotherapy; IMRT = intensity-modulated radiotherapy; RT = radiotherapy; 3DCRT = three-dimensional conformal radiotherapy.

In general, evidence on tumor control and survival outcomes is sparse. Table 9 shows that statistically significant differences were inconsistently reported for overall survival, local control, or locoregional control among studies of 3DCRT versus IMRT in any regimen compiled there. All abstracted data are shown in detail in Table B-6.

### Strength of Evidence for Key Question 2

To evaluate the SOE, we used an approach specifically developed by the AHRQ EPC program and referenced in the Methods Guide.20 This approach is based on a system initially described by the GRADE Working Group. It explicitly addresses four required domains: risk of bias, directness, consistency, and precision, as outlined in the Methods section.

Table 10 shows the SOE for the comparative effects of 3DCRT, IMRT, SBRT, and PBT on oncologic outcomes in the treatment of head and neck cancer patients. The criteria we used to arrive at the SOE ratings are outlined in the Methods section of the update. Details on how the SOE ratings were determined are summarized in Table 10.

Table 10 SOE for Key Question 2: Oncologic outcomes

Intervention | Comparator | Treatment Regimen | Outcome | Evidence Base (Number of Patients) | Risk of Bias | Directness | Consistency | Precision | Overall SOE
3DCRT | IMRT | CCRT | Overall survival | Three studies (four reports) including the Gupta (2012) and Rathod (2013) RCTs25,26,29,33 (N=509) | Moderate One “fair” quality small RCT (N=60, Gupta, 2012; N=60, Rathod, 2013) plus two “poor” quality non-randomized studies result in a provisional “moderate” study limitations rating. | Direct All three studies (four reports) directly compared IMRT and 3DCRT. | Consistent All three studies (four reports) showed no statistically significant difference between 3DCRT and IMRT in rate of overall survival at 2 or 5 years. | Imprecise The Gupta RCT25 was likely not sufficiently powered to detect slight changes in rates of overall survival with IMRT compared with 3DCRT, particularly in the face of much larger, albeit “poor” quality non-RCT evidence. | Insufficient A “high” provisional SOE based on the Gupta RCT25 was reduced three levels for three reasons: (1) imprecise rating based on the small size of the Gupta RCT and its nonsignificant result; (2) the two nonrandomized studies were of “poor” quality, heterogeneous, and subject to a high risk of bias, thus increasing the risk of bias to “moderate” for the body of evidence; and, (3) the relative larger size of these 2 studies compared to Gupta accounting for 88% of all patients in the body of evidence, obscure the findings of the latter, resulting in an overall SOE rating of “insufficient”.
3DCRT | IMRT | CCRT | Locoregional control | Two studies (three reports) including the Gupta (2012) and Rathod (2013) RCTs25,26,33 (N=305) | Moderate One “fair” quality RCT (N=60, Gupta, 2012; N=60, Rathod, 2013) and a much larger “poor” quality nonrandomized study result in a “moderate” study limitations rating. | Direct Both studies (three reports) directly compared IMRT and 3DCRT. | Consistent Both studies (three reports) showed no statistically significant difference between 3DCRT and IMRT in rate of overall survival at 2 or 5 years. | Imprecise The Gupta RCT25 was likely not sufficiently powered to detect slight changes in rates of locoregional control with IMRT compared with 3DCRT, particularly in the face of much larger, albeit “poor” quality non-RCT evidence. | Insufficient A “high” provisional SOE based on the Gupta RCT25 was reduced three SOE levels as outlined above for overall survival. Note the patients in the nonrandomized study comprised more than 80% of the evidence base, obscuring Gupta’s results.
3DCRT | IMRT | CCRT | Local control | One study29 (N=204) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | CCRT | Disease-free survival | One study29 (N=204) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | CCRT ± surgery | Local control | One study28 (N=82) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | Postoperative RT | Overall survival | One study31 (N=81) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | Postoperative RT | Local control | One study31 (N=81) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | Postoperative RT | Disease-free survival | One study31 (N=81) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | RT ± CCT ± surgery | Overall survival | One study36 (N=67) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | RT ± CCT ± surgery | Locoregional control | One study36 (N=67) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | RT ± CCT ± surgery | Distant metastasis-free survival | One study36 (N=67) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | RT ± CCT | Overall survival | Three studies35,38,39 (N=423) | High Three “poor” quality nonrandomized studies result in a “high” study limitations rating. | Direct All three studies directly compared IMRT and 3DCRT. | Inconsistent The Huang 2013 study35 showed a statistically significant benefit (p=0.004) of IMRT compared with 3DCRT as it pertains to overall survival at 5 years, while the remaining two studies report no statistical difference based on RT technique at 2 or 3 years. | Imprecise The “poor” quality, nonrandomized Huang 2013 study35 was likely not sufficiently powered to detect slight changes in rates of overall survival of IMRT compared with 3DCRT, particularly in the face of the much larger, “poor” quality nonrandomized studies which report no benefit of IMRT. | Insufficient The three nonrandomized studies were “poor” quality and heterogeneous, with high risk of bias that compromises the value of their results.
3DCRT | IMRT | RT ± CCT | Locoregional control | Two studies35,39 (N=264) | High Two “poor” quality nonrandomized studies result in a “high” study limitations rating. | Direct Both studies directly compared IMRT and 3DCRT. | Consistent Both studies report a statistically significant difference between 3DCRT and IMRT in rate of locoregional control at 3 or 5 years. | Imprecise Due to the “poor” quality, nonrandomized design of these studies, it is likely that they were not sufficiently powered to detect slight changes in the rates locoregional control with IMRT as compared with 3DCRT. | Insufficient The two nonrandomized studies were “poor” quality and heterogeneous, with high risk of bias that compromises the value of their results.
3DCRT | IMRT | RT ± CCT | Distant relapse | One study35,39 (N=181) | High | Direct | Unknown | Imprecise | Insufficient
3DCRT | IMRT | RT ± CCT | Disease-free survival | Two studies35,38 (N=242) | High Two “poor” quality nonrandomized studies result in a “high” study limitations rating | Direct Both studies directly compared IMRT and 3DCRT | Inconsistent The Huang 2013 study35 reports a statistically significant benefit (p=0.046) of IMRT compared with 3DCRT as it pertains to disease-free survival at 5 years, while the Lohia 2014 study38 reports a directionally opposite and statistically nonsignificant benefit of 3DCRT over IMRT at 2 years. | Imprecise Due to the “poor” quality, nonrandomized design of these studies, it is likely that they were not sufficiently powered to detect slight changes in the rates of disease-free survival with IMRT as compared with 3DCRT. | Insufficient The two nonrandomized studies were “poor” quality and heterogeneous, with high risk of bias that compromises the value of their results.
3DCRT | SBRT PBT | Any regimen | Any outcome | No evidence | No evidence | No evidence | No evidence | No evidence | No evidence
IMRT | SBRT PBT | Any regimen | Any outcome | No evidence | No evidence | No evidence | No evidence | No evidence | No evidence

Abbreviations: CCT = concurrent chemotherapy; CCRT = concurrent chemoradiotherapy; IMRT = intensity-modulated radiotherapy; PBT = proton-beam radiotherapy; RCT = randomized controlled trial; RT = radiotherapy; SBRT = stereotactic body radiotherapy; SOE = strength of evidence; 3DCRT = three-dimensional conformal radiotherapy.

We determined that new evidence, including one “fair” quality RCT (Gupta, 2012),25 is insufficient to support a conclusion on the relative effect of IMRT and 3DCRT on overall survival or locoregional control rates in a regimen of CCRT. New evidence is insufficient to form conclusions on the effect of any other RT modality comparison for any oncologic outcome in any other regimen we identified in this update.

## Key Question 3 Comparative Effectiveness of 3DCRT, IMRT, SBRT, or PBT for Specific Patient and Tumor Characteristics

### Key Points

- In CER No. 20, no comparative studies addressed these issues. In this update, we did not identify any new evidence that specifically addressed Key Question 3.
- Therefore insufficient evidence exists to form conclusions about the comparative effects or SOE on 3DCRT, IMRT, SBRT, or PBT based on specific patient and tumor characteristics.

## Key Question 4 Comparative Effectiveness of 3DCRT, IMRT, SBRT, or PBT Because of Differences in User Experience, Treatment Planning, Treatment Delivery, and Target Volume Delineation

### Key Points

- In CER No. 20, no comparative studies addressed these issues. In this update, we did not identify any new evidence that specifically addressed Key Question 4.
- Therefore insufficient evidence exists to form conclusions about the comparative effects or SOE on 3DCRT, IMRT, SBRT, or PBT based on specific patient and tumor characteristics.