# References

1 Samson DJRT, Rothenberg BM, et al. Comparative effectiveness and safety of radiotherapy treatments for head and neck cancer. Comparative Effectiveness Review No. 20. (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center under Contract No. 290-02-0026). Rockville, MD. Agency for Healthcare Research and Quality, 2009. May. 2010.
2 Tsertsvadze AAN, Skidmore B, et al. AHRQ Comparative Effectiveness Review Surveillance Program: Comparative effectiveness and safety of radiotherapy treatments for head and neck cancer. AHRQ Website. 2012.
3 Erickson BA, Wilson JF. Nasopharyngeal brachytherapy. Am J Clin Oncol. Oct. 1993;16(5):424-443. [pmid: 8213626].
4 Esche BA, Haie CM, Gerbaulet AP, Eschwege F, Richard JM, Chassagne D. Interstitial and external radiotherapy in carcinoma of the soft palate and uvula. Int J Radiat Oncol Biol Phys. Sep. 1988;15(3):619-625. [pmid: 3138213].
5 Jorgensen K, Elbrond O, Andersen AP. Carcinoma of the lip. A series of 869 cases. Acta Radiol Ther Phys Biol. Jun. 1973;12(3):177-190. [pmid: 4749173].
6 Marchese MJ, Nori D, Anderson LL, Hilaris BS. A versatile permanent planar implant technique utilizing iodine-125 seeds imbedded in gelfoam. Int J Radiat Oncol Biol Phys. May. 1984;10(5):747-751. [pmid: 6735761].
7 Marcus RB Jr, Million RR, Mitchell TP. A preloaded, custom-designed implantation device for stage T1–T2 carcinoma of the floor of mouth. Int J Radiat Oncol Biol Phys. Jan. 1980;6(1):111-113. [pmid: 7364600].
8 Mendenhall NP, Parsons JT, Cassisi NJ, Million RR. Carcinoma of the nasal vestibule. Int J Radiat Oncol Biol Phys. May. 1984;10(5):627-637. [pmid: 6429094].
9 Mendenhall NP, Parsons JT, Cassisi NJ, Million RR. Carcinoma of the nasal vestibule treated with radiation therapy. Laryngoscope. May. 1987;97(5):626-632. [pmid: 3573913].
10 Jemal A, Bray F, Center MM, Ferlay J, Ward E, Forman D. Global cancer statistics. CA: A Cancer Journal for Clinicians. 2011;61(2):69-90. [pmid: 21296855].
11 Pfister DG, Ang K-K, Brizel DM, et al. Head and Neck Cancers. Journal of the National Comprehensive Cancer Network. June. 1. 2011. 2011;9(6):596-650. [pmid: 21636536].
12 Chaturvedi AK, Engels EA, Pfeiffer RM, et al. Human papillomavirus and rising oropharyngeal cancer incidence in the United States. Journal of Clinical Oncology. November. 10. 2011. 2011;29(32):4294-4301. [pmid: 21969503].
13 Sturgis EM, Ang KK. The epidemic of HVP-associated oropharyngeal cancer is here: Is it time to change our treatment paradigms?. Journal of the National Comprehensive Cancer Network. 2011;9(6):665-673. [pmid: 21636538].
14 Ang KK, Harris J, Wheeler R, et al. Human papillomavirus and survival of patients with oropharyngeal cancer. N Engl J Med. Jul. 1. 2010;363(1):24-35. [pmid: 20530316].
15 National Cancer Institute. Fact Sheet: Radiation Therapy for Cancer. (www.cancer.gov/cancertopics/factsheet/Therapy/radiation). Accessed August 13, 2014.
16 Bucci M, Bevan A, Roach M III. Advances in radiation therapy: conventional to 3D, to IMRT, to 4D, and beyond. CA Cancer J Clin. 2005;55:117-134. [pmid: 15761080].
17 Chavaudra J, Bridier A. Definition of volumes in external radiotherapy: ICRU reports 50 and 62. Cancer Radiother. Oct. 2001;5(5):472-478. [pmid: 11715299].
18 Lee N, Puri DR, Blanco AI, et al. Intensity-modulated radiation therapy in head and neck cancers: An update. Head & Neck. 2007;29(4):387-400. [pmid: 16358297].
19 Siddiqui F, Raben D, Lu JJ, et al. Emerging applications of stereotactic body radiation therapy for head and neck cancer. Expert Rev Anticancer Ther. Sep. 2011;11(9):1429-1436. [pmid: 21929316].
20 Helfand M, Balshem H. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. August. 2009. Rockville, MD. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January 2014. Chapters available at www.effectivehealthcare.ahrq.gov.
21 Tsertsvadze A, Maglione M, Chou R, et al. Updating comparative effectiveness reviews: current efforts in AHRQ’s Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1208-1215. [pmid: 21684114].
22 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
23 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010;63:513-523. [pmid: 19595577].
24 Brown P, Brunnhuber K, Chalkidou K, et al. How to formulate research recommendations. BMJ. Oct. 14. 2006;333(7572):804-806. [pmid: 17038740].
25 Gupta T, Agarwal J, Jain S, et al. Three-dimensional conformal radiotherapy (3D-CRT) versus intensity modulated radiation therapy (IMRT) in squamous cell carcinoma of the head and neck: a randomized controlled trial. Radiother Oncol. Sep. 2012;104(3):343-348. [pmid: 22853852].
26 Rathod S, Gupta T, Ghosh-Laskar S, Murthy V, Budrukkar A, Agarwal J. Quality-of-life (QOL) outcomes in patients with head and neck squamous cell carcinoma (HNSCC) treated with intensity-modulated radiation therapy (IMRT) compared to three-dimensional conformal radiotherapy (3D-CRT): evidence from a prospective randomized study. Oral Oncol. Jun. 2013;49(6):634-642. [pmid: 23562564].
27 Al-Mamgani A, Mehilal R, van Rooij PH, Tans L, Sewnaik A, Levendag PC. Toxicity, quality of life, and functional outcomes of 176 hypopharyngeal cancer patients treated by (chemo)radiation: the impact of treatment modality and radiation technique. Laryngoscope. Aug. 2012;122(8):1789-1795. [pmid: 22833307].
28 Al-Mamgani A, Monserez D, Rooij P, Verduijn GM, Hardillo JA, Levendag PC. Highly-conformal intensity-modulated radiotherapy reduced toxicity without jeopardizing outcome in patients with paranasal sinus cancer treated by surgery and radiotherapy or (chemo)radiation. Oral Oncol. Sep. 2012;48(9):905-911. [pmid: 22584070].
29 Al-Mamgani A, van Rooij P, Verduijn GM, Mehilal R, Kerrebijn JD, Levendag PC. The impact of treatment modality and radiation technique on outcomes and toxicity of patients with locally advanced oropharyngeal cancer. Laryngoscope. Feb. 2013;123(2):386-393. [pmid: 23404489].
30 Chen AM, Farwell DG, Luu Q, Vazquez EG, Lau DH, Purdy JA. Intensity-modulated radiotherapy is associated with improved global quality of life among long-term survivors of head-and-neck cancer. Int J Radiat Oncol Biol Phys. Sep. 1. 2012;84(1):170-175. [pmid: 22300572].
31 Dirix P, Vanstraelen B, Jorissen M, Vander Poorten V, Nuyts S. Intensity-modulated radiotherapy for sinonasal cancer: Improved outcome compared to conventional radiotherapy. International Journal of Radiation Oncology Biology Physics. 2010;78(4):998-1004. [pmid: 20338694].
32 Guan X, Wang X, Liu Y, Hu C, Zhu G. Lymph node metastasis in sinonasal squamous cell carcinoma treated with IMRT/3D-CRT. Oral Oncology. 2013;49(1):60-65. [pmid: 22884302].
33 Lambrecht M, Nevens D, Nuyts S. Intensity-modulated radiotherapy vs. parotid-sparing 3D conformal radiotherapy. Effect on outcome and toxicity in locally advanced head and neck cancer. Strahlenther Onkol. Mar. 2013;189(3):223-229. [pmid: 23319256].
34 Ozyigit G, Cengiz M, Yazici G, et al. A retrospective comparison of robotic stereotactic body radiotherapy and three-dimensional conformal radiotherapy for the reirradiation of locally recurrent nasopharyngeal carcinoma. International Journal of Radiation Oncology Biology Physics. 2011;81(4):e263-e268. [pmid: 21514737].
35 Huang HI, Chan KT, Shu CH, Ho CY. T4-locally advanced nasopharyngeal carcinoma: prognostic influence of cranial nerve involvement in different radiotherapy techniques. Scientific World Journal. 2013;2013:439073. [pmid: 24385882].
36 Kong M, Hong SE, Choi J, Kim Y. Comparison of survival rates between patients treated with conventional radiotherapy and helical tomotherapy for head and neck cancer. Radiation Oncology Journal. 2013;31(1):1-11. [pmid: 23620863].
37 Kruser TJ, Rice SR, Cleary KP, et al. Acute hematologic and mucosal toxicities in head and neck cancer patients undergoing chemoradiotherapy: A comparison of 3D-CRT, IMRT, and helical tomotherapy. Technology in Cancer Research and Treatment. 2013;12(5):383-389. [pmid: 23547974].
38 Lohia S, Rajapurkar M, Nguyen SA, Sharma AK, Gillespie MB, Day TA. A comparison of outcomes using intensity-modulated radiation therapy and 3-dimensional conformal radiation therapy in treatment of oropharyngeal cancer. JAMA Otolaryngol Head Neck Surg. Apr. 1. 2014;140(4):331-337. [pmid: 24557509].
39 Mok G, Gauthier I, Jiang H, et al. Outcomes of intensity-modulated radiotherapy versus conventional radiotherapy for hypopharyngeal cancer. Head Neck. Mar. 2. 2014. [pmid: 24590756].
40 Nutting CM, Morden JP, Harrington KJ, et al. Parotid-sparing intensity modulated versus conventional radiotherapy in head and neck cancer (PARSPORT): a phase 3 multicentre randomised controlled trial. Lancet Oncol. Feb. 2011;12(2):127-136. [pmid: 21236730].
41 Chao KS, Deasy JO, Markman J, et al. A prospective study of salivary function sparing in patients with head-and-neck cancers receiving intensity-modulated or three-dimensional radiation therapy: initial results. Int J Radiat Oncol Biol Phys. Mar. 15. 2001;49(4):907-916. [pmid: 11240231].
42 Marchal C, Lapeyre M, Beckendorf V, et al. Preliminary results of the assessment of intensity modulated radiotherapy (IMRT) for prostatic and head and neck tumors (STIC 2001). Cancer Radiother. Nov. 2004;8(Suppl 1):S121-127. [pmid: 15679257].
43 Chen AM, Daly ME, Bucci MK, et al. Carcinomas of the paranasal sinuses and nasal cavity treated with radiotherapy at a single institution over five decades: are we making improvement?. Int J Radiat Oncol Biol Phys. Sep. 1. 2007;69(1):141-147. [pmid: 17459609].
44 Fang FM, Tsai WL, Chen HC, et al. Intensity-modulated or conformal radiotherapy improves the quality of life of patients with nasopharyngeal carcinoma: comparisons of four radiotherapy techniques. Cancer. Jan. 15. 2007;109(2):313-321. [pmid: 17154159].
45 Golen MSK, Wygoda A, et al. The influence of radiation technique on xerostomia in head and neck cancer patients: prospective study. Rep Pract Oncol Radiother. 2007;12(5):253-260.
46 Hodge CW, Bentzen SM, Wong G, et al. Are we influencing outcome in oropharynx cancer with intensity-modulated radiotherapy? An inter-era comparison. Int J Radiat Oncol Biol Phys. Nov. 15. 2007;69(4):1032-1041. [pmid: 17967300].
47 Rades D, Fehlauer F, Wroblesky J, Albers D, Schild SE, Schmidt R. Prognostic factors in head-and-neck cancer patients treated with surgery followed by intensity-modulated radiotherapy (IMRT), 3D-conformal radiotherapy, or conventional radiotherapy. Oral Oncol. Jul. 2007;43(6):535-543. [pmid: 17005437].
48 Fang FM, Chien CY, Tsai WL, et al. Quality of life and survival outcome for patients with nasopharyngeal carcinoma receiving three-dimensional conformal radiotherapy vs. intensity-modulated radiotherapy-a longitudinal study. Int J Radiat Oncol Biol Phys. Oct. 1. 2008;72(2):356-364. [pmid: 18355980].
49 Gomez DR, Hoppe BS, Wolden SL, et al. Outcomes and prognostic variables in adenoid cystic carcinoma of the head and neck: a recent experience. Int J Radiat Oncol Biol Phys. Apr. 1. 2008;70(5):1365-1372. [pmid: 18029108].
50 Palazzi M, Tomatis S, Orlandi E, et al. Effects of treatment intensification on acute local toxicity during radiotherapy for head and neck cancer: prospective observational study validating CTCAE, version 3.0, scoring system. Int J Radiat Oncol Biol Phys. Feb. 1. 2008;70(2):330-337. [pmid: 17881148].
51 Rusthoven KE, Raben D, Ballonoff A, Kane M, Song JI, Chen C. Effect of radiation techniques in treatment of oropharynx cancer. Laryngoscope. Apr. 2008;118(4):635-639. [pmid: 18176348].
52 Vergeer MR, Doornaert PA, Rietveld DH, Leemans CR, Slotman BJ, Langendijk JA. Intensity-modulated radiotherapy reduces radiation-induced morbidity and improves health-related quality of life: results of a nonrandomized prospective study using a standardized follow-up program. Int J Radiat Oncol Biol Phys. May. 1. 2009;74(1):1-8. [pmid: 19111400].
53 Langendijk JA, Doornaert P, Rietveld DH, Verdonck-de Leeuw IM, Leemans CR, Slotman BJ. A predictive model for swallowing dysfunction after curative radiotherapy in head and neck cancer. Radiother Oncol. Feb. 2009;90(2):189-195. [pmid: 19167120].
54 Peng G, Wang T, Yang KY, et al. A prospective, randomized study comparing outcomes and toxicities of intensity-modulated radiotherapy vs. conventional two-dimensional radiotherapy for the treatment of nasopharyngeal carcinoma. Radiother Oncol. Sep. 2012;104(3):286-293. [pmid: 22995588].