# Methods

## Overview

This section describes the methods used to produce this CER update. Methodological practices followed were derived from the Methods Guide and its subsequent updates.20 We also consulted the article by Tsertsvadze et al. on methods to update CERs.21 The main parts in this section reflect the elements of the protocol established for the CER; certain methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.

## Study Inclusion Criteria

We included only full-length reports that describe the final results of randomized controlled trials (RCTs) and nonrandomized comparative studies (observational, case-control, and cohort studies) of populations, interventions, comparisons, outcomes, treatment intervals, and settings that are part of the PICOTS (see above).

We excluded conference abstracts and other non-peer-reviewed sources as well as noncomparative (single-arm) studies from this CER update. In preparation of CER No. 20, we collected a substantial body of evidence from single-arm studies. In our analysis, we found that single-arm studies were very heterogeneous, with differences in patient populations, RT methods, treatment era, and adjunct treatments used, particularly cytotoxic chemotherapy regimens. As a consequence, we determined that the evidence was uninformative and not adequate for making valid comparisons or hypothesis generation.

We considered including dosimetry studies in CER No. 20, and this update. For both reports, our ultimate conclusion not to include dosimetry studies was agreed upon among our EPC team, among AHRQ personnel, and in discussion with our TEP. The primary rationale for this conclusion is that dosimetry studies do not provide a link to actual clinical outcomes that are realized by patients. Dosimetry modeling is clearly needed to advance research in RT methods, but it does not provide evidence for clinical efficacy.

## Literature Search

### Search Strategies

An experienced medical librarian designed and performed all searches for this CER update. The literature search for the update was backdated to 12 months before the final literature search for CER No. 20 (dated September 28, 2009). For SBRT, the literature was searched electronically for citations from January 1, 1990, through April 2013. The entire search was updated May 1, 2014, after the draft was posted for peer review by AHRQ.

We searched the following databases:

- MEDLINE^®^
- EMBASE^®^
- Cochrane Controlled Trials Register

## Data Abstraction and Data Management

Literature search results were transferred to EndNote^®^ and subsequently into Distiller for study screening.

### Review of Titles and Abstracts

We developed data collection forms for abstract review, full-text review, and data extraction. Using the study selection criteria for screening titles and abstracts, each citation was marked as eligible for review as full-text article or ineligible for full-text review. Two CER team members performed the initial title and abstract screen. A training set of 25–50 article selections were examined initially to assure uniform application of screening criteria. Full-text review was performed if it was unclear whether the study selection criteria were satisfied. Reasons for study exclusions at the title and abstract screening phase were not noted. To be excluded, a study must have been independently excluded by both team members. Discrepancies were decided by consensus opinion; a third reviewer was consulted if necessary.

### Full-Text Review

Full-text articles were reviewed in the same fashion against the PICOTS to determine their inclusion in the systematic review. The reason for excluding an article retrieved in full-text was recorded in the Distiller database. Although an article could be excluded for multiple reasons, only the principal reason identified was noted.

### Data Abstraction

For studies that met the inclusion criteria, we abstracted data into tables created in the Systematic Review Data Repository, with elements defined in an accompanying data dictionary. A training set of five articles was abstracted by one team member and reviewed by the Team Lead to ensure consistency. Each article included was abstracted by a single reviewer. A second reviewer assessed the data extraction against the original articles for quality control. Identified differences in data coding between the abstractor and reviewer were resolved by consensus.

The data elements abstracted included the following:

- Patient characteristics, including:
  ○ Age (excluding pediatric patients, 18 years or younger)
  ○ Sex
  ○ Race/ethnicity
  ○ Tumor location
  ○ Tumor stage
- Treatment characteristics, including:
  ○ Type of RT (e.g., photons, electrons, protons)
  ○ Total RT dose
  ○ Fractionation schedule
  ○ Imaging methods used to guide RT (e.g., CT, implanted fiducials, bony landmarks) and the frequency of imaging to assess therapy (e.g., daily, weekly, monthly)
  ○ Other prior or concurrent treatment modalities (e.g., systemic chemotherapy)
  ○ Number of prior lines of treatment
- Outcome assessment
  ○ Identified final outcome (see PICOTS and Analytical Framework)
  ○ Identified intermediate outcomes (see PICOTS and Analytical Framework)
  ○ Adverse event response criteria
  ○ Followup frequency and duration
  ○ Data analysis details, including:
    – Statistical analyses (statistical test/estimation results)
    – Summary measures
    – Sample variability measures
    – Precision of estimate
    – p-values
  ○ Regression modeling techniques
    – Model type
    – Candidate predictors and methods for identifying candidates
    – Univariate analysis results
    – Selected predictors and methods for selecting predictors
    – Testing of assumptions
    – Inclusion of interaction terms
    – Multivariable model results
    – Discrimination or validation methods and results
    – Calibration or “goodness-of-fit” results

### Evidence Tables

The same abstraction tables were used for all studies. The dimensions of each evidence table may vary by Key Question, but the tables contain common elements such as author, year of publication, sample size, study type, intervention(s), and comparator(s). We report outcome data in strata according to prognostic or other patient-related factors (e.g., tumor stage) provided they were reported separately or could be inferred from the study in question.

## Assessment of Methodological Risk of Bias (Quality or Limitations) of Individual Studies

In adherence to the Methods Guide,20 the general approach to grading the quality or limitations of individual comparative studies was performed by using a United States Preventive Services Task Force (USPSTF) method (Appendix B).22 Individual study quality assessment accounted for the following study elements:

- Number of participants and flow of participants through steps of study
- Treatment-allocation methods (including concealment)
- Use of blinding
- Study design (prospective vs. retrospective)
- Use of an independent outcome assessor

The quality of the abstracted studies was assessed independently by two investigators. Discordant quality assessments were resolved with input from a third reviewer, if necessary.

## Data Synthesis

Our experience with CER No. 20, for which we did not perform a quantitative data synthesis, led us to rule out a quantitative synthesis for this update. Our analysis of the literature indicated a substantial degree of interstudy heterogeneity; given the small numbers of studies, we concluded a qualitative synthesis would be appropriate. The qualitative synthesis emphasized comparative studies sorted by specific head-to-head comparisons of RT modalities, specific treatment regimens, patient characteristics, specific outcomes, and status relative the evidence hierarchy and study quality assessment.

### Grading the SOE for Individual Comparisons and Outcomes

Studies were assessed for relevance against target populations, interventions of interest, and outcomes of interest. The system used for rating the strength of the overall body of evidence is outlined in the recently updated (2013) chapter from the “Methods Guide”20 and is based on a system developed by the GRADE Working Group.23

This system explicitly addresses the following domains: study limitations, directness, consistency, precision, and reporting bias. Additional (optional) domains, including strength of association (magnitude of effect), dose-response association, and plausible confounding, could be addressed if appropriate. Table 1 describes the four required and three optional domains and their scores and applications.

Table 1 SOE rating domains: required and optional

Domain Name | Domain Type | Domain Definition and Elements | Domain Score and Application
Study limitations | Required | This domain reflects the degree to which included studies for a given outcome have high likelihood of protection against bias (i.e., good internal validity), assessed through two main elements:; - Study design: Whether included studies are RCTs or other designs such as nonexperimental or observational studies.; - Study conduct: Considers aggregation of ratings of risk of bias of the individual studies under consideration. | Score as one of three levels, separately by type of study design:; - Low level of study limitations; - Moderate level of study limitations; - High level of study limitations
Directness | Required | Directness relates to:; - Whether evidence links interventions directly to a health outcome of specific importance for the review, and; - Whether the comparisons are based on head-to-head studies.; The EPC should specify the comparison and outcome for which the SOE grade applies. Evidence may be indirect in several situations such as:; - The outcome being graded is considered intermediate (i.e., laboratory test results) in a review that is focused on clinical health outcomes (i.e., morbidity, mortality).; - Data do not come from head-to-head comparisons but rather from two or more bodies of evidence to compare interventions A and B (e.g., studies of A vs. placebo and B vs. placebo, or studies of A vs. C and B vs. C but not direct studies of A vs. B).; - Data are available only for proxy respondents (e.g., from family members or nurses) instead of directly from patients.; Indirectness always implies that more than one body of evidence is required to link interventions to the most important health outcome. | Score as one of two levels:; - Direct; - Indirect; If the domain score is indirect, the EPC should specify what type of indirectness accounts for the rating.
Consistency | Required | Consistency is the degree to which included studies find either the same direction or similar magnitude of effect. The EPC can assess this through two main elements:; - Direction of effect: Effect sizes have the same sign (i.e., are on the same side of no effect or a minimally important difference).; - Magnitude of effect: The range of effect sizes is similar. The EPC may consider the overlap of confidence intervals when making this evaluation.; The importance of direction vs. magnitude of effect will depend on the Key Question and EPC judgments. | Score as one of three levels:; - Consistent; - Inconsistent; - Unknown (e.g., single study); Single-study evidence bases (including mega-trials) cannot be judged with respect to consistency. In that instance, use “Consistency unknown (single study).”
Precision | Required | Precision is the degree of certainty surrounding an effect estimate with respect to a given outcome, based on the sufficiency of sample size and number of events. Several caveats must be considered in determining the precision of a body of evidence.; - A body of evidence will generally be imprecise if the optimal information size is not met. Optimal information size refers to the minimum number of patients (and events when assessing dichotomous outcomes) needed for an evidence base to be considered adequately powered.; - If an EPC performed a meta-analysis, then it may also consider whether the confidence interval crossed a threshold for a minimally important difference.; - If meta-analysis is infeasible or inappropriate, the EPC may consider the narrowness of the range of confidence intervals or the significance level of p-values in the individual studies in the evidence base. | Score as one of two levels:; - Precise; - Imprecise; A precise estimate is one that would allow users to reach a clinically useful conclusion (e.g., treatment A is more effective than treatment B).
Reporting bias | Required | Reporting bias results from selectively publishing or reporting research findings bases on the favorability of direction or magnitude of effect. It includes:; - Study publication bias (i.e., nonreporting of the full study); - Selective outcome reporting bias (i.e., nonreporting or incomplete reporting of unplanned outcomes); - Selective analysis reporting bias (i.e., reporting one or more favorable analyses for a given outcome while not reporting other, less favorable analyses).; Assessment of reporting bias for individual studies depends on many factors, including availability of study protocols, unpublished study documents, and patient-level data. Detecting such bias is likely with access to all relevant documentation and data pertaining to a journal publication, but such access is rare. Because methods to detect reporting bias in observational studies are less certain, this guidance does not require EPCs to assess it for such studies. | Score as one of two levels:; - Suspected; - Undetected; Reporting bias is suspected when:; - Testing for funnel plot asymmetry demonstrates a substantial likelihood of bias, and/or; - A qualitative assessment suggests the likelihood of missing studies, analyses, or outcomes data that may alter the conclusions from the reported evidence.; Undetected reporting bias includes all alternative scenarios.
Dose-response association | Optional | This association, either across or within studies, refers to a pattern of a larger effect with greater exposure (dose, duration, adherence) | This domain should be considered when studies in the evidence base have noted levels of exposure. Score as one of two levels:; - Present: Dose-response pattern observed.; - Undetected: No dose-response pattern observed (dose-response relationship not present or could not be determined).
Plausible confounding that would decrease observed effect | Optional | Occasionally, in an observational study, plausible confounding would work in the direction opposite that of the observed effect. Had these confounders not been present, the observed effect would have been even larger than the one observed. | This domain should be considered when plausible confounding exists that would decrease the observed effect. Score as one of two levels:; - Present: Confounding factors that would decrease the observed effect may be present and have not been controlled for.; - Absent: Confounding factors that would decrease the observed effect are not likely to be present or have been controlled for.
Strength of association (magnitude of effect) | Optional | Strength of association refers to the likelihood that the observed effect is large enough that it could not have occurred solely as a result of bias from potential confounding factors. | This additional domain should be considered when the effect size is particularly large. Score as one of two levels:; - Strong: Large effect size that is unlikely to have occurred in the absence of a true effect of the intervention.; - Weak: Small enough effect size that it could have occurred solely as a result of bias from confounding factors.

Abbreviations: RCT = randomized controlled trial; EPC = Evidence-based Practice Center; SOE = strength of evidence.

Grading a body of evidence involves consideration of the type of studies included in the review. For assessing a clinical outcome, RCT evidence is considered the best evidence, based purely on study design. In the EPC grading system, a body of evidence including RCTs is assigned a provisional SOE grade of “high.” This may change, however, after assessment of study limitations based on how the RCTs were conducted, and other domains such as directness, consistency, and precision.

By contrast, evidence from nonrandomized comparative studies is assumed to pose a greater risk of having study limitations because of the typically higher risk of bias attributable to a lack of randomization and inability to control for critical confounding factors. This type of evidence is generally assigned a provisional initial SOE grade of “low.” The latter may be moved up to “moderate” when study limitations are graded as low or moderate, based on controls for risk of bias through study conduct or analysis. The initial SOE for nonrandomized comparative study evidence may also be initially graded as “moderate” for certain outcomes such as important harms or for certain Key Questions when it is deemed at less risk for study limitations secondary to a lower risk of bias related to potential confounding.

A few real-world examples of grading evidence are illustrative of the literature encountered on this topic. In synthesizing a body of evidence represented by a single RCT rated as good quality and multiple nonrandomized comparative studies of lower quality (e.g., primarily poor), we would start with the findings from the “best available evidence” (the good quality RCT) and a high initial SOE. The study limitation domain in this instance would initially be rated as low. If the RCT and nonrandomized studies report results in opposite directions of effect, the body of evidence could be rated as having unknown consistency, thus reducing the overall strength by one level. Concluding unknown consistency is based on lack of confirmation for the direction and would be justified particularly if biases and confounding in nonrandomized studies do not have a predictable direction. However, if the differences are less dramatic and could be explained by bias in a predictable direction, then it may be considered consistent. Direct head-to-head comparisons of an intervention and comparator that report on an important health outcome lead to a rating of direct on the directness domain. In a qualitative synthesis of this hypothetical body of evidence, insufficient size (compared with the optimal information size) of the RCT would render the aggregate results imprecise on the precision domain, reducing strength by at least one level. According to EPC convention, the path through all required domains would take the strength from high through two reductions to a final strength of low.

A second example would comprise a body of comparative evidence that included multiple, nonrandomized design studies. Even if direct results are consistent and precise, this example would have a starting study limitations grade of high and SOE of low. If all studies were deemed to be poor quality and poorly conducted, the body of evidence could be downgraded further to insufficient. However, application of the optional domains, particularly magnitude of effect in favor of an intervention, could raise the strength one level to low or, perhaps, moderate if sufficiently robust.

The overall SOE grade is classified into four categories, as shown in Table 2. Specific outcomes and comparisons to be rated depend on the evidence found in the literature review. The grade rating was made by independent reviewers, and disagreements were resolved by consensus adjudication.

Table 2 Overall strength-of-evidence categories and criteria for assignment

Grade | Definition | Criteria for Assignment
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. | The body of evidence has few or no deficiencies. We believe that the findings are stable.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. | The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. | The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. | No evidence is available or the body of evidence has unacceptable deficiencies, precluding judgment.

We report a summary of key outcomes for each Key Question in a table that lists the major outcomes, the study design and number of studies of each type plus number of subjects, the findings, and the direction and magnitude of effect where applicable. The overall SOE grade for each outcome is specifically reported in this table.

## Assessing Applicability

We assessed applicability of findings with the AHRQ Comparative Effectiveness “Methods Guide” using the PICOTS (Population, Intervention, Comparator, Outcome, Timing, Setting) framework.20,24 Included studies were assessed for relevance against target populations, interventions and comparators of interest, and outcomes of interest. We anticipated that results would be applicable only to the specialized populations of interest by Key Question.