# Introduction

## Objectives

In May 2010, the Agency for Healthcare Research and Quality (AHRQ) published the results of Comparative Effectiveness Review (CER) No. 20, “Comparative Effectiveness and Safety of Radiotherapy Treatments for Head and Neck Cancer,” prepared by the Blue Cross and Blue Shield Association Evidence-based Practice Center (EPC).1 CER No. 20 examined evidence on clinical outcomes achieved with two-dimensional radiotherapy (2DRT), three-dimensional conformal RT (3DCRT), intensity-modulated RT (IMRT), and proton-beam RT (PBT). The main finding of CER No. 20 was that late xerostomia was reduced and quality of life (QOL) domains related to xerostomia were improved in patients treated with IMRT compared with those who underwent 3DCRT or 2DRT. Evidence was insufficient to draw conclusions on overall survival or tumor control; adverse events other than late xerostomia (e.g., mucositis, dysphagia, skin toxicities, or osteoradionecrosis of the jaw); whether patient and tumor characteristics affected relative outcomes; or whether physician experience and treatment characteristics affected relative clinical outcomes such as survival or treatment-associated adverse events.

In 2012, AHRQ published a surveillance report that used methods developed by the RAND and Ottawa EPCs to prioritize an update of AHRQ CER No. 20 in 2013.^2^ In preparing this update, we examined the applicability of opposed beam 2DRT and brachytherapy (BT) in modern radiation oncology practice. Our conclusion, based on the current literature and input from our Technical Expert Panel (TEP) members, was that 2DRT is no longer in routine use in the United States for definitive treatment of head and neck cancer, thus we excluded it from the update.

Brachytherapy is an invasive technique that was the first form of RT in clinical use, dating back to 1901. Historically, it has been used extensively in many tumor types, including head and neck cancer. The primary advantage of BT over traditional opposed external beam 2DRT has been its capability to conform a high, localized radiation dose to the implanted tumor, limiting exposure to noninvolved tissues. However, as conformal external beam RT methods (e.g., 3DCRT and IMRT) have become more prevalent in the past 2 decades, this advantage has been mitigated.

Brachytherapy can be used in select head and neck cancer cases as a means of dose escalation in conjunction with external beam irradiation.3,4 However, this practice has become uncommon because sufficient dose escalation can usually be achieved in these cases with a noninvasive approach (i.e., conformal RT). Brachytherapy alone is very rarely employed, except with small (T1) tumors of the nasal vestibule, lip, or oral cavity.5–9 These presentations of head and neck cancers are relatively uncommon (1 percent to perhaps 5 percent of all cases), and RT is typically not first-line treatment in many cases. Therefore, because BT alone for primary management of head and neck malignancies has limited applicability in modern radiation oncology practice, we did not seek evidence of it for this current CER; we focused instead on RT modalities that are used as the sole RT intervention for a given presentation of head and neck cancer.

For this update, we reviewed and assessed new evidence on the comparative effectiveness of 3DCRT, IMRT, and PBT. We also systematically reviewed and assessed evidence on stereotactic body RT (SBRT), a newer RT modality that was not widely available when we prepared CER No. 20. This update used the same Key Questions as in CER No. 20 and, for the most part, the same methods and search strategies, modified to address the changes in the list of interventions. We organized clinical evidence according to treatment regimen, abstracted only from comparative studies (randomized or nonrandomized) of the conformal RT methods used in treatment for any head and neck cancer.

### Epidemiology and Burden of Head and Neck Cancer

Head and neck cancer is a heterogeneous disease characterized by complex clinical and pathologic presentations. Squamous cell carcinoma of the head and neck (SCCHN) specifically arises in the squamous epithelium of the upper aerodigestive tract (oral cavity, larynx, hypopharynx, oropharynx, nasopharynx, paranasal sinuses/nasal cavity). SCCHN constitutes approximately 90 percent of all head and neck cancers, and accounted for approximately 3 percent (about 50,000) of all new cancer cases and 2 percent (approximately 12,000) of all cancer deaths in 2010 in the U.S.10 While these cancers in total comprise a relatively small percentage of all cancers, cumulatively they are the sixth most common cancer worldwide, with notable exceptions of high nasopharyngeal cancer incidence in South Eastern China and South Eastern Asia and high oral cavity cancer incidence in Melanesia and South Central Asia. More than 600,000 people were diagnosed with SCCHN worldwide in 2008.^10^

Major risk factors for the development of head and neck cancer include tobacco and alcohol abuse, with other less common risk factors including occupational exposures, nutritional deficiencies, and poor oral health.11 Viral etiologies have also been established, with human papillomavirus (HPV) infection appearing to be a risk factor, particularly within the oropharynx, in younger people without a history of tobacco or alcohol abuse. The reported proportion of oropharyngeal cancers attributable to HPV in the U.S. has increased from 16.3 percent during the 1980s to 72.7 percent during the 2000s.12,13 Careful anatomic site stratification has shown that the age-adjusted incidence of oropharyngeal cancer is rising dramatically (estimated to be a 5 percent annual increase). In addition to HPV, an association has been made between Epstein-Barr virus and nasopharyngeal cancer.

## Overview of Multimodal Clinical Management of Head and Neck Cancer

Most patients with SCCHN present with locally advanced but curable disease; only a small percentage of these patients have demonstrable distant metastases. Treatment decisions are primarily determined by the size, location, and grade of the primary tumor; the extent of nodal involvement; and the estimated functional impact of therapy. Patient characteristics may include substantial comorbidities and poor performance status that would be considered in devising a comprehensive treatment plan.11

Aggressive multimodality treatments with curative intent may include surgery, RT, and chemotherapy. Radiotherapy is a mainstay of treatment, offered to nearly 75 percent of all head and neck cancer patients with either curative or palliative intent. Radiotherapy may be used alone or as a part of multimodality approach, often with significant long-term side effects. In planning this CER, we sought to account for multimodal treatment strategies by organizing evidence according to treatments used in comparative studies of the RT modalities. Toxicities associated with RT represent important clinical outcomes that can substantially reduce QOL and the ability of cancer patients to tolerate and complete the entire planned course of treatment.

The main challenge in RT for any type of cancer is to attain the highest probability of tumor control or cure with the least amount of morbidity and toxicity. However, improved outcomes with aggressive RT regimes come at the cost of increased treatment toxicity, mainly due to the close proximity of critical organs and the often large irradiation fields necessary to effect local tumor control in head and neck cancer patients. For example, xerostomia is the most prevalent toxicity of RT to the head and neck and is a major cause of reduced QOL. In addition to patient perception of mouth dryness, it leads to impaired speech and swallow function, all of which also contribute to decreased QOL. Other prominent, RT-associated toxicities include salivary gland dysfunction, accelerated dental caries, and osteoradionecrosis.

Although RT-associated toxicities are highly problematic in any patient with head and neck cancer, such adverse events may assume greater importance in patients identified with HPV-positive compared with those with HPV-negative disease.13 Patients with HPV-positive oropharynx cancer not only appear to have a different clinical phenotype from HPV-negative cancers, but they also have had better outcomes in multiple large studies, even when correcting for other known prognostic factors.14 This trend has led investigators to research deintensification of treatment for patients with HPV-related head and neck cancers to limit toxicities, and alternatively intensification of treatment to improve tumor control in those with a significant HPV-negative cancer with a smoking history.11,13 However, it is important to note that current practice guidelines, such as the National Comprehensive Cancer Network (NCCN), do not recommend treatment differences based on HPV status (with perhaps the exception of HPV+ unknown primary cancers). In preparing this update, we sought to identify, where possible, HPV-positive patients as separate entities from HPV-negative patients.

## RT in Head and Neck Cancer

### Overview

We present a brief overview of the different types of RT modalities for those less familiar with the specific technologies. For those seeking further details on the different approaches, information is available from the National Cancer Institute and citations therein. 15

Radiotherapy designs have evolved over the past 30 years from being based on two-dimensional (2D) to three-dimensional (3D) images, incorporating increasingly complex computer algorithms.16 2DRT consists of a single beam from one to four directions with the radiation fields designed on 2D fluoroscopic simulation images. A quest to improve on the survival rates and adverse effect profile of 2DRT led to widespread adoption and application of 3D imaging-based methods for definitive (curative) treatment of patients with SCCHN, with general abandonment of 2DRT in this role in the U.S.

Conformal RT refers to modalities in which radiation beams are “shaped” to cover the tumor volume plus a surrounding tissue margin to treat microscopic disease that may reside there. To standardize image-based tumor volume definitions for 3D radiation planning, the Internal Commission of Radiation Units and Measurements created terminology for use across institutions. Definitions include gross tumor volume (GTV), clinical target volume (CTV), and planning target volume (PTV).17 The GTV pertains to gross disease identified by clinical workup (e.g., physical exam and imaging), CTV includes the GTV and any areas at risk for microscopic disease, and PTV is an expansion of the CTV by a margin (usually 3–5 mm in the head and neck patient) to account for patient or organ motion and day-to-day setup variation.

#### Conformal RT Modalities

Conformal external-beam photon-based RT modalities used to treat SCCHN include 3DCRT, IMRT, and SBRT, which is also known as stereotactic ablative RT.16 For purposes of this update, we use the term SBRT. Charged particle-based conformal external-beam therapy such as PBT is also available. Here we briefly review each conformal RT modality in this CER update.

##### Three-Dimensional Conformal Radiotherapy

Three dimensional conformal RT uses 3D anatomic information from diagnostic computed tomography (CT) scans in a forward-planned process to deliver multiple, highly focused beams of radiation that converge at the tumor site. This allows accurate and precise conformity of the radiation to the typically irregular tumor volume, theoretically reducing exposure of surrounding tissues when compared with traditional opposed-beam 2DRT.16

##### Intensity-Modulated Radiotherapy

In the 1990s, technological and computer treatment planning advances led to the development of IMRT.16,18 The technique of IMRT is more complex and resource-intensive than 3DCRT. It uses a CT-based inverse-planning process to deliver ionizing radiation conformally to the target. By altering the beam intensity using tungsten-based multileaf collimators, IMRT theoretically reduces radiation dose to adjacent organs or tissues at risk (e.g., the parotid glands). However, with IMRT a larger volume of uninvolved adjacent tissues may be exposed to ionizing radiation than 3DCRT. Standard IMRT techniques are referred to as sliding window, step and shoot, and volumetric modulated arcs; any of these was noted in this CER as IMRT.

##### Stereotactic Body Radiotherapy

Stereotactic body RT is a type of 3D conformal RT that is used to deliver tumoricidal doses of radiation in fewer treatment sessions than used in 3DCRT or IMRT regimens.19 Regimens used in SBRT generally comprise a total dose equal to that delivered by 3DCRT or IMRT, but typically in eight fractions rather than 25 or more fractions. As a technique, SBRT is defined by robust immobilization, highly precise, image-guided patient setup, and high dose-per-fraction irradiation focused on gross disease with a minimal margin for setup error. There are many different platforms for SBRT, but especially in head and neck cancer therapy there is less tracking than for other sites, and 4D simulation is not used.

##### Proton-Beam Radiotherapy

Although PBT is not widely available in the U.S., it has become increasingly available in the last few years. Like IMRT or SBRT, PBT is a 3D conformal RT technique; however, it delivers charged particles at tumoricidal doses rather than photons. PBT has a physical advantage over photon therapy because it lacks an “exit dose” from tumor tissue. Unlike photons, which release energy along their path traversing tumors, protons deposit the majority of their energy at the end of their path through tissue, in the tumor volume, resulting in what is referred to as the Bragg peak.

## Summary

The optimal means of delivering external beam ionizing radiation in sufficient doses to cure a patient with SCCHN requires a fine balance between treatment effectiveness and associated toxicity. In CER No. 20, the compiled evidence demonstrated an advantage for IMRT over 3DCRT and 2DRT in reducing late xerostomia and improving measures of xerostomia-related QOL. Evidence was insufficient to demonstrate any relative difference between modalities in measures such as overall survival or tumor control. Since CER No. 20 was published, a newer conformal technology—SBRT—has come into practice, whereas 2DRT has fallen out of use in the U.S. A surveillance study prepared in 2012 by the Ottawa and RAND EPCs suggested rationale to update CER No. 20, based on signals of new evidence that would change several conclusions of that report. Taken together, the emergence of new technology and evidence suggesting potential differences in some comparative outcomes prompted AHRQ to prioritize this update of CER No. 20.

## Key Questions

The proposed Key Questions for CER No. 20, entitled “Comparative Effectiveness and Safety of Radiotherapy Treatments for Head and Neck Cancer,” were posted for public comment for 4 weeks during its development. At that time, changes to the Key Questions and the PICOTS were made based on comments received and discussion with the TEP for the report. In the surveillance assessment used to determine the priority to update the 2010 report, the language of the Key Questions was modified slightly, but unchanged in meaning.

The Key Questions we used for this update follow below. In addition to 3DCRT, IMRT, and PBT, we included SBRT, which was not part of CER No. 20. Based on input from TEP discussions and a review of the literature, we excluded 2DRT from further consideration and did not include brachytherapy for reasons listed previously in the report. In response to TEP input, we also revised the language of Key Question 4 to expand the list of potential variables to consider.

Key Question 1 What is the comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT regarding adverse events and QOL?
Key Question 2 What is the comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT regarding tumor control and patient survival?
Key Question 3 Are there differences in the comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT for specific patient and tumor characteristics?
Key Question 4 Is there variation in the comparative effectiveness of 3DCRT, IMRT, SBRT, and PBT because of differences in user experience, treatment planning, treatment delivery, and target volume delineation?

## PICOTS

### Population(s)

#### Key Questions 1–4

Populations of interest included patients with head and neck cancer. To define what constitutes head and neck cancer, we consulted clinical resources such as the National Cancer Institute’s (NCI) Physician Data Query Cancer Information Summary and the National Comprehensive Cancer Network (NCCN).11 The consensus definition of head and neck cancer includes tumors of:

- Larynx
- Pharynx (hypopharynx, oropharynx, and nasopharynx)
- Lip and oral cavity
- Paranasal sinus and nasal cavity
- Salivary gland
- Occult primary of the head and neck

The following tumors were excluded:

- Brain tumors
- Skull base tumors
- Uveal/choroidal melanoma, other ocular and eyelid tumors
- Otologic tumors
- Cutaneous tumors of the head and neck (including melanoma)
- Thyroid cancer
- Parathyroid cancer
- Esophageal cancer
- Trachea tumors

All therapeutic strategies were included. RT can be delivered as a primary (curative) intent therapy or as an adjunct to surgery. Chemotherapy can also be given as an adjunct to RT, particularly in patients with more advanced cancer (i.e., stages III or IV). We sought direct evidence for one RT modality compared with another, with or without chemotherapy or surgery.

### Interventions

#### Key Questions 1–4

- 3DCRT: defined as any treatment plan where CT-based forward treatment planning is used to delineate radiation beams and target volumes in three dimensions.
- IMRT: defined as any treatment plan using intensity-modulated radiation beams and computerized inverse treatment planning.
- SBRT: defined as conformal RT (forward- or reverse-planned) delivered in 3–5 relatively larger doses of ionizing radiation than typically delivered in a standard conformal schedule of 25–35 doses.
- PBT: defined as any treatment plan using proton-beam radiation.

RT may be delivered as part of a multimodal treatment strategy if the comparisons only differ with respect to the RT given.

### Comparators

#### Key Questions 1–4

All therapies were compared with each other as part of a continuum of treatment for patients with head and neck cancer. Thus, we included studies in which an RT method was compared with a different method (e.g., with or without chemotherapy or surgery). We included all studies in which we could be reasonably certain additional treatments were contemporary and similar, leaving the major comparison that between RT modalities; those that we could not ascertain from the publication would be excluded.

To ensure chemotherapy or other treatments were similar and contemporary, we consulted accepted guidelines such as those from NCCN or NCI. We did not extract details on chemotherapy dosages or schedules, but rather ascertained their degree of general similarity and the proportions of patients who receive and complete such regimens. We categorized and synthesized evidence according to overall treatment (e.g., concurrent chemoradiotherapy or adjuvant RT), not mixing these regimens in the strength of evidence (SOE) synthesis.

### Outcomes

#### Key Questions 1, 3, and 4

Final outcomes: QOL and adverse events including: radiation-induced toxicities, xerostomia, mucositis, taste changes, dental problems, and dysphagia.

Intermediate outcomes: Salivary flow and probability of completing treatment according to protocol.

We sought evidence related to user experience, treatment planning, and target volume delineation within the context of Key Question 4.

#### Key Questions 2–4

Final outcomes: Overall survival and cancer-specific survival.

Intermediate outcomes: Local control and time to recurrence.

### Timing

All durations of followup were considered.

### Settings

Typically community-based versus tertiary or academic medical centers.

## Analytic Framework

Figure 1 provides an analytic framework illustrating the population, RT modalities to be compared, outcomes, and adverse effects that guided our literature search and synthesis. It links the RT modalities of interest directly with final health outcomes (e.g., overall survival) and adverse events (e.g., xerostomia) as well as indirectly with final outcomes via intermediate outcomes (e.g., local control, disease-free survival).

Figure 1 Analytic framework for comparative effectiveness of RT for head and neck cancer

Figure 1 depicts the Key Questions (KQs) within the context of the PICOTS described in the previous section. In general, the figure illustrates how 3DCRT, IMRT, SBRT, or PBT may result in intermediate outcomes (e.g., local tumor control, disease-free survival) and final health outcomes (e.g., overall survival, cancer-specific survival, QOL). Also, adverse events (e.g., radiation-associated xerostomia and salivary dysfunction, dysphagia, mucositis, otologic dysfunction, visual dysfunction) may occur at any point after the treatment is received.

Abbreviations: 3DCRT = 3-dimensional conformal radiation therapy; IMRT = intensity-modulated radiation therapy; KQ = Key Question; PBT = proton-beam radiation therapy; QOL = quality of life; RT = radiation therapy; SBRT = stereotactic body radiation therapy.

Figure 1 depicts the key questions (KQs) within the context of the PICOTS described in the previous section. In general, the figure illustrates how the interventions 3DCRT, IMRT, SBRT, and PBT may result in intermediate outcomes (e.g., local tumor control, disease-free survival) and long-term outcomes (e.g., overall survival, cancer-specific survival, QOL). Also, adverse events (e.g., radiation-associated xerostomia and salivary dysfunction, dysphagia, mucositis, otologic dysfunction, visual dysfunction) may occur at any point after the treatment is received.

## Organization of This Report

In the following sections of this CER update, we outline the methods used in its preparation, including literature search strategies, methods used to select studies for inclusion, data elements and their abstraction, tabulation of results, assessment of study quality and risk of bias, and how we evaluated the SOE. In the Results section, we provide an overview of the literature search results and study inclusion and exclusion. We then present evidence for each Key Question, using bulleted key points and a summary of the results and tabulature of such. The Discussion section contains our assessment of the SOE as related to the conclusions of CER No. 20. Finally, we discuss the applicability of the evidence to clinical decisionmaking and gaps in the evidence base in the Discussion section. The report concludes with an overall summary that ties it together to the CER No. 20 findings.