# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Elliot Abemayor, M.D., Ph.D., FACS
  Co-Director, Head and Neck Oncology Program
  Professor of Head and Neck Surgery
  Ronald Reagan—UCLA Medical Center
  David Geffen School of Medicine at UCLA
  Los Angeles, CA
- Søren Bentzen, D.Sc., Ph.D.
  Professor, Human Oncology and Medical Physics
  Varian Visiting Professor to the Radiation Therapy Oncology Group (RTOG)
  University of Wisconsin School of Medicine and Public Health
  Madison, WI
- David M. Brizel, M.D.
  Leonard Prosnitz Professor of Radiation Oncology
  Duke University School of Medicine
  Durham, NC
- Sarah Hope Kagan, Ph.D., R.N.
  Lucy Walker Honorary Term Professor of Gerontological Nursing
  University of Pennsylvania School of Nursing
  Philadelphia, PA
- William M. Lydiatt, M.D.
  Professor of Otolaryngology
  Director of Head and Neck Surgery
  University of Nebraska Medical Center
  Omaha, NE
- David G. Pfister, M.D.
  Chief, Head and Neck Oncology Service
  Memorial Sloan-Kettering Cancer Center
  New York, NY
- David J. Sher, M.D., M.P.H.
  Assistant Professor of Radiation Oncology
  Rush University Medical Center
  Chicago, IL