# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- James A. Deye, Ph.D.
  Program Director, National Cancer Institute
  Division of Cancer Treatment & Diagnostics
  Bethesda, MD
- Avraham Eisbruch, M.D.
  Professor of Radiation Oncology
  University of Michigan Comprehensive Cancer Center
  Ann Arbor, MI
- Arlene Forastiere, M.D.
  Professor of Oncology
  Johns Hopkins University and the Sydney Kimmel Comprehensive Cancer Center
  Baltimore, MD
- B. Ashleigh Guadagnolo, M.D., M.P.H.
  Associate Professor of Radiation Oncology
  Associate Professor of Health Services Research
  The University of Texas MD Anderson Cancer Center
  Houston, TX
- Alexander Langerman, M.D., FACS
  Assistant Professor of Surgery
  The University of Chicago Pritzker School of Medicine
  Chicago, IL
- Christine Lantier, M.S.N., R.N., O.C.N.
  Clinical Supervisor
  Memorial Sloan-Kettering Cancer Center
  New York, NY